# METHODS

## TOPIC DEVELOPMENT

This topic was nominated by Linda Kinsinger, MD, MPH, Chief Consultant for Preventive Medicine, National Center for Health Promotion and Disease Prevention; Gordon Schectman, MD, Chief Consultant for Primary Care Services; and Michael Goldstein, MD, Associate Chief Consultant for Preventive Medicine. The evidence review examines the benefits and harms of the Mediterranean diet compared to other diets. Key questions and inclusion criteria were derived with input from the topic nominators and a technical expert panel.

## SEARCH STRATEGY

We searched MEDLINE (Ovid), CINAHL, and the Cochrane library for articles published from 1990 through August 2015. Our search was limited to studies of adults published in the English language. The search included the MeSH (Medical Subject Headings) terms fruit; vegetables; nuts; bread; cereals; seeds; fatty acids, monusaturated; seafood; and diet, Mediterranean. To address Key Question 3, an additional search was done in all 3 databases adding the terms adherence and patient compliance. The searches were also repeated with the addition of disease-specific terms to find articles specific to cancer, rheumatoid arthritis, and cognitive impairment. The full search strategies are presented in Appendix A. We also obtained articles by hand-searching the reference lists of systematic reviews and included studies. A separate search was also done in all 3 databases to identify systematic reviews of cohort studies reporting on cardiovascular disease, diabetes, and all-cause mortality.

## DEFINITIONS

We included studies with diets that met the criteria defined by a recent Cochrane Review, that is to say, labelled a Mediterranean diet or meeting 2 or more of the following components: 1. high monounsaturated:saturated fat ratio (use of olive oil as main cooking ingredient); 2. high consumption of fruits/vegetables; 3. high consumption of legumes; 4. high consumption of grains/cereals; 5. moderate red wine consumption; 6. moderate consumption of dairy products; and 7. low consumption of meat and meat products (replaced by increased consumption of fish). All included studies met this minimum definition. The names for the diets included terms such as Mediterranean diet, prudent diet, healthy Nordic diet, and healthy pattern.

## STUDY SELECTION

Abstracts from MEDLINE (n = 7,672) were reviewed in duplicate independently by investigators and research associates. Abstracts from the CINAHL database (n = 131) and Cochrane Library (n = 1,799) were reviewed by a co-investigator or research associate. Trained researchers identified articles published in peer-reviewed journals related to one of the Key Questions (KQs). For studies addressing KQs 1 and 2 in diseases other than cancer, RA, or cognitive impairment we included RCTs or controlled clinical trials (CCTs) with at least 100 subjects followed for at least one year. For studies of RA and cognitive impairment we included RCTs, CCTs, and cohort studies with any number of participants and no limit on follow-up time. For studies of cancer and for KQ3 we included RCTs and cohort studies with at least 100 participants followed for at least one year. In addition, in order to be included, studies addressing KQ3 must have taken place in the United States or Canada. For all questions and outcomes, we excluded case series, case reports, qualitative reports, narrative reviews, editorials, or letters. Studies must have also reported one of our outcomes of interest as defined in the Analytic Framework (Figure 1) and PICOTS (above).

All included studies met our definition of a Mediterranean diet. In the randomized trials, the composition of the intervention diets were defined a priori. In the cohort studies, food frequency surveys (either self-administered or administered by research staff) were typically used to categorize subjects' diets based on validated dietary indices. Commonly used indices include the Mediterranean-diet score, the alternate Mediterranean-diet score (aMED), the Healthy Eating Index (HEI), and the Alternate Healthy Eating Index (aHEI). For these indices we generally compared the highest quantile of conformity to a Mediterranean diet to the lowest. We excluded the following:

- Studies that did not involve outpatient adults;
- Studies with diets that were not labelled Mediterranean and did not test or measure a diet that met our criteria for a Mediterranean diet (stated above);
- Studies in women who were pregnant or lactating; and
- For KQ3, studies that were conducted in countries other than the US and Canada.

Full-text reports of studies identified as potentially eligible were obtained for further review using the inclusion and exclusion criteria described above. Each article was independently reviewed by 2 trained researchers. Reasons for excluding a study at full-text review were noted.

## DATA ABSTRACTION

Study characteristics (goal of intervention, inclusion/exclusion criteria, diet descriptions, follow-up, and patient characteristics) as well as outcomes (mortality, health-related quality of life, adverse events, satisfaction, new onset of disease, disease progression/recurrence, and adherence) were extracted onto evidence tables by one investigator or research associate and verified by another. The systematic reviews of cohort studies reporting on cardiovascular disease, diabetes, and all-cause mortality were summarized narratively.

## RISK OF BIAS ASSESSMENT

We assessed the risk of bias for RCTs using the following criteria: sequence generation, allocation concealment, blinding, incomplete outcome reporting, and selective outcome reporting – a modification of the Cochrane approach to determining risk of bias.20 For cohort studies risk of bias was determined based on: population (representativeness of sample, uniform application of inclusion/exclusion criteria), outcomes (important outcomes assessed and reported, appropriate length of follow-up), measurement (outcome assessment same for all participants, accurate and reliable tools used), and confounding (appropriate confounding factors included in analysis). Individual studies were rated as low, medium, or high risk of bias. Low risk of bias RCTs had adequate allocation concealment, blinding, and outcome reporting. Low risk of bias cohort studies had appropriate populations, assessed important outcomes with adequate follow-up, used appropriate outcome measurement tools, and adjusted for important potential confounding factors.

## DATA SYNTHESIS

Data were summarized by outcome. If applicable, we pooled outcomes data from RCTs and cohort studies separately using Comprehensive Meta Analysis Version 3 (Biostat, Englewood, New Jersey). Most of the studies reported hazard ratios (HR), which we treated as risk ratios (RR). We extracted the HR of the highest conformity to a Mediterranean diet, based on Mediterranean-diet scores, that was compared to the lowest conformity (the reference). Random effects models were used to calculate pooled RRs. If provided, we used the adjusted risk estimates from multivariate models. If HRs or RRs were not reported, we calculated RRs based on the numbers of events and populations reported for each of the diet groups. We measured the magnitude of statistical heterogeneity with the I^2^ statistic (75% indicates substantial heterogeneity).21

## RATING THE BODY OF EVIDENCE

We rated the overall strength of the body of evidence for select outcomes (all-cause mortality [KQ1, KQ2], cancer incidence [KQ1], and cognitive functioning [KQ1]) using the method reported by Owens et al.22

## PEER REVIEW

A draft version of this report was reviewed by content experts and clinical leadership. Reviewers' comments and our responses are presented in Appendix B and the report was modified as needed.