# INTRODUCTION

A large number of epidemiologic studies have investigated the association between diet and mortality and morbidity. Of particular recent interest is the Mediterranean diet, first described by Ancel Keys over 50 years ago.1 This diet is characterized by high intake of olive oil, fruits and vegetables, whole grains and cereals, legumes, fish, and nuts; low intake of red meat, dairy products, and sweets; and moderate intake of red wine with meals.2 Epidemiologic studies have shown that the incidence of cardiovascular disease in populations that consume such diets is lower than in populations that consume a more typical “Western” diet that is rich in red meat, dairy products, processed and artificially sweetened foods, and salt with minimal intake of fruits, vegetables, fish, legumes, and whole grains.3-5

Based on these epidemiologic studies, several randomized controlled trials were conducted to test the hypothesis that adopting a Mediterranean diet in adulthood reduces chronic disease burden (eg, incidence of and/ or mortality from cardiovascular disease, cancer, type 2 diabetes mellitus [T2DM], hypertension, cognitive impairment, and kidney disease) and/or all-cause mortality (viz, PREDIMED, Lyon Heart Study, THIS-DIET).6-8 These trials included populations from a variety of geographical locations and with a spectrum of demographic and clinical characteristics.

Although several systematic reviews of the relevant observational studies and clinical trials have been published,9-19 the VA's Evidence-based Synthesis Program, in conjunction with the Office of Quality and Performance and in response to a request from the VA's National Center for Health Promotion and Disease Prevention and Primary Care Services, commissioned the present study to update prior reviews and to specifically assess the implications for the treatment and prevention of common chronic conditions in the Veteran population. We conferred with the topic nominators and Technical Expert Panel (TEP) members and other experts inside and outside the VA to select the parameters of the review, including patient characteristics, interventions, and outcomes (Figure 1, Analytic Framework).

Figure 1 Analytic Framework

The final Key Questions are:

Key Question 1: Is the Mediterranean diet more effective than other diets in preventing death or the development of type 2 diabetes mellitus, cardiovascular disease, cancer, hypertension, cognitive impairment, or kidney disease?

- Key Question 1a: Do the effects vary by gender, age, or BMI?

Key Question 2: Compared to other diets, is the Mediterranean diet associated with fewer adverse outcomes (including death) or less disease progression in people who already have diabetes, cardiovascular disease, cancer, hypertension, cognitive impairment, rheumatoid arthritis, or kidney disease?

- Key Question 2a: Do the effects vary by gender, age, or BMI?

Key Question 3: What is the observed adherence to the Mediterranean diet in studies conducted in the United States or Canada?

## PICOTS

Population: Adults (age 18 or older), not pregnant or lactating, and not hospitalized or institutionalized. Subgroups of interest: people with type II diabetes, cardiovascular disease, rheumatoid arthritis, cancer, hypertension, cognitive impairment, or kidney disease; different genders, ages, and BMIs.

Interventions: A Mediterranean-style diet (ie, labelled as a Mediterranean diet or consisting of at least 2 of the following: 1. high monounsaturated:saturated fat ratio (use of olive oil as main cooking ingredient); 2. high consumption of fruits and vegetables; 3. high consumption of legumes; 4. high consumption of grains/cereals; 5. moderate red wine consumption; 6. moderate consumption dairy products; and 7. low consumption of meat and meat products (replaced by increased consumption of fish)

Comparator: Any other type of diet (eg, Western, low fat, vegetarian)

Outcomes: NOTE: Definitions for all outcomes followed definitions used in the included studies. T2DM, hypertension, and kidney disease were considered present only if the study recorded a clinical diagnosis had been made (ie, not just by laboratory values obtained in the study)

KQ1: mortality, quality of life, new onset of T2DM, hypertension, cardiovascular disease (CVD) (myocardial infarction [MI], stroke, or congestive heart failure), kidney disease, cancer, and cognitive impairment (dementia, Alzheimer's disease [AD], or mild cognitive impairment [MCI])

KQ2:

A. For populations with diabetes, heart disease, kidney disease, and/or hypertension at baseline:
  1. Mortality
  2. Quality of life
  3. Progression of disease, ie:
    a. Development of retinopathy, neuropathy, end-stage renal disease, or congestive heart failure
    b. New amputation
    c. New myocardial infarction, stroke, or revascularization procedure
B. For populations with cancer at baseline:
  1. Mortality (all-cause, cancer-specific)
  2. Quality of life
  3. Progression of disease or recurrence
C. For populations with rheumatoid arthritis at baseline:
  1. Pain
  2. Quality of life
  3. Functional status
D. For populations with cognitive impairment at baseline:
  1. Diagnosis of dementia
  2. Quality of life
  3. Functional status

KQ1, KQ2: Any adverse events related to diet in RCTs

KQ3: Adherence measures

Timing: At least one year of follow-up, except for studies of rheumatoid arthritis or cognitive impairment

Setting: Outpatient

Study Type:

KQ1 or KQ2:

Studies of patients with or at risk for cardiovascular disease, hypertension, diabetes, or kidney disease – RCTs of at least 100 people followed for at least one year

Studies of patients with or at risk for cancer – RCTs or cohort studies with at least 100 participants and at least one year follow-up

Studies of patients with or at risk for rheumatoid arthritis or cognitive impairment – randomized controlled trials (RCTs) or cohort studies of any size or follow-up duration

KQ3: RCTs of at least 100 people followed for at least one year