# LITERATURE FLOW

Figure 1 Literature Flow Key Questions 1 and 2 Randomized Controlled Trials

Figure 2 Literature Flow Key Questions 1 and 2 Cohort Studies (Cancer, RA, Cognitive)

Figure 3 Literature Flow Key Question 3