# EVIDENCE TABLES

## KEY QUESTION 1

Table 1 Key Question 1 – Study, Intervention, and Patient Characteristics

Table 2 Key Question 1 – Mortality, Quality of Life, Adverse Events, and Patient Satisfaction

Table 3 Key Question 1 – New Onset of Cardiovascular-related Conditions (Myocardial Infarction, Stroke, Congestive Heart Failure) and Rhematoid Arthritis

Table 4 Key Question 1 – New Onset of Kidney Disease, Cancer, and Cognitive Impairment

## KEY QUESTION 2

Table 5 Key Question 2 – Study, Intervention, and Patient Characteristics

Table 6 Key Question 2 – Outcomes for Populations with Diabetes, Heart Disease, Kidney Disease, and/or Hypertension (Part 1)

Table 7 Key Question 2 – Outcomes for Populations with Diabetes, Heart Disease, Kidney Disease, and/or Hypertension (Part 2)

Table 8 Key Question 2 – Outcomes for Populations with Diabetes, Heart Disease, Kidney Disease, and/or Hypertension (Part 3)

Table 9 Key Question 2 – Outcomes for Populations with Cancer

Table 10 Key Question 2 – Outcomes for Populations with Rheumatoid Arthritis

Table 11 Key Question 2 – Outcomes for Populations with Cognitive Impairment

## KEY QUESTION 3

Table 12 Key Question 3 – Study, Intervention, and Patient Characteristics

Table 13 Key Question 3 – Adherence