# PEER REVIEW COMMENTS/AUTHOR RESPONSES

Question Text | Comment | Response
Are the objectives, scope, and methods for this review clearly described? | Yes | Thank you
Are the objectives, scope, and methods for this review clearly described? | Yes
Are the objectives, scope, and methods for this review clearly described? | Yes
Are the objectives, scope, and methods for this review clearly described? | Yes
Are the objectives, scope, and methods for this review clearly described? | Yes
Are the objectives, scope, and methods for this review clearly described? | Yes
Is there any indication of bias in our synthesis of the evidence? | No | Thank you
Is there any indication of bias in our synthesis of the evidence? | No
Is there any indication of bias in our synthesis of the evidence? | No
Is there any indication of bias in our synthesis of the evidence? | No
Is there any indication of bias in our synthesis of the evidence? | No
Is there any indication of bias in our synthesis of the evidence? | No
Are there any [underlined: published] or [underlined: unpublished] studies that we may have overlooked? | No | No response needed
Are there any [underlined: published] or [underlined: unpublished] studies that we may have overlooked? | No
Are there any [underlined: published] or [underlined: unpublished] studies that we may have overlooked? | No
Are there any [underlined: published] or [underlined: unpublished] studies that we may have overlooked? | No
Are there any [underlined: published] or [underlined: unpublished] studies that we may have overlooked? | No
Are there any [underlined: published] or [underlined: unpublished] studies that we may have overlooked? | No
Additional suggestions or comments can be provided below. If applicable, please indicate the page and line numbers from the draft report. | page 5 lines 45-53. The Women's Health Initiative is called out in the text but PREDIMED is not. Seems that consistency should be greater. page 6, line 41 and page 44, line 25. is there really evidence that a low fat diet is healthy? Isn't this all called into question? I think there is greater evidence of the healthiness of a vegetarian diet. Page 12: What is the “T” in “PICOTS”? Pge 18, line 23. It would help to define “k” somewhere. Some readers may not be acquainted with the terminology. Page 43, line 12; I wonder whether you want to use “possibly” rather than “likely”. Although I would really like to believe that the difference in outcomes for WHI compared with PREDIMED is the difference in the diet, do we have enough evidence to write that it is “likely”? General comment: I would like to see text in the conclusion that states something to the effect that “in retrospect, the definition of ‘Mediterranean diet’ may have been overly broad, and in turn, this may have influenced the conclusions of the analysis. For example, a diet of hamburgers and French fries would qualify as long at it was eaten with red wine and no milk.” I acknowledge the paragraph about asking which components are the active ingredients in the Mediterranean diet, but I think that directly pointing to the issue of defining the diet is also very important. | page 5. We have named the PREDIMED study in this statement. page 6. Thank you for the suggestion. We have removed low fat diet from these lines. page 12. The “T” is for Timing (now added to the PICOTS) page 18. We have defined k in several places. page 43 and General comment: We revised the language in the report to address both of these comments.
Additional suggestions or comments can be provided below. If applicable, please indicate the page and line numbers from the draft report. | The authors reviewed and synthesized the literature and conducted a meta-analysis for randomized clinical trials and observations studies about the benefits (or not) of the Mediterranean diet (MedDiet) pattern in the primary and secondary prevention of disease or chronic conditions. Comments:; 1. Title: I suggest changing the title of the paper as not all studies included in the meta-analysis were interventions. Dietary intake as an exposure in an observational study was observed.; 2. I disagree with the authors' definition of the MedDiet and the statement (page 14 Methods) that ‘there is no universally accepted definition of the Mediterranean diet’. There are a numerous publications and a couple reviews below about the MedDiet which clearly describe the components of the MedDiet pattern (references a and b).; a. Trichopoulou et al. Definitions and potential health benefits of the Mediterranean diet: views from experts around the world. BMC Medicine 2014, 12:112.; b. Willett WC et al; Mediterranean Diet Pyramid: A cultural model for healthy eating. Am J Clin Nutr. 1995; 61(suppl): 1402S-1406S.; In addition, the MedDiet is not a ‘low fat’ diet even though the ‘low fat’ diet may include many of the components the authors describe in their definition. The key component of the MedDiet is olive oil, as reported in numerous publications including the ones I suggest above. Therefore, it seems that the definition of a MedDiet should include olive oil plus 2 of the other components. The authors use a commonly used ratio [monounsaturated fat (MUFA)/saturated fat ratio] as one of the components to define the MedDiet and further explain that most of the MUFA should come from olive oil. However, it is not clear to me if the source of monounsaturated fat intake is known (ie, was the source of MUFA reported in published papers). Given that most of the instruments used in studies to assess dietary intake are food frequency questionnaires, it is not clear if source of MUFA was available. As you may know, a large source of MUFA in the US diet is from meat. And meat has been positively related to numerous chronic diseases. In the U.S., very little olive oil is consumed. Olive oil is not the main cooking oil used in the U.S.; Finally, several studies categorized as ‘Mediterranean’ in the current study were in fact ‘low fat’ diets (e.g. WHI diet modification trial). In WHI, one of the goals of the diet intervention was to reduce fat intake to 20% of calories which is clearly low fat. However, fat intake for a MedDiet pattern is about 40% from calories. Further, the PREDIMED study investigators compared a MedDiet pattern to a low fat diet pattern – and found the MedDiet to be beneficial in reducing incident CVD events compared to the low fat diet pattern. So it is puzzling that the WHI diet pattern (which is low fat) was labeled as ‘Mediterranean-like diet’ in this review. Thus, the study investigators meta-analyzed very different diet patterns (although according to their study definition – they were labeled the Mediterranean diet).; I believe the authors have combined diet patterns that are very different - apples and oranges – which may explain their study results. If the authors changed their definition for the MedDiet pattern, then the meta-analysis should be conducted again.; 3. For key question 3, I suggest the authors compare the results of studies conducted in European countries to the studies conducted in the U.S. given that the diet patterns defined as ‘Mediterranean’ would be quite different between the 2 continents. In Europe – the Mediterranean diet would include ‘olive oil’ while in the U.S. the Med diet pattern would not include ‘olive oil’ and most likely be ‘low fat’ diet patterns.; 4. Throughout the text, the authors refer to some number of RCTs and observational studies. Perhaps these studies can be referenced so the reader is aware of which study the author is referring. Also, in the Discussion – mention is made of a ‘high quality RCT or lower quality RCT…..’, so again, please reference these. | 1. Thank you for the suggestion. We have changed the title; 2. We chose our definition based on the recent Cochrane review and with approval from our stakeholders and Technical Expert Panel.; We have examined the references cited in the reviewer comment and believe that these references, and others, do, in fact, emphasize that there is no universally accepted definition of the Mediterranean diet.; 3. We did an exploratory analysis creating forest plots with outcomes based on country and found no pattern.; 4. We have added more references to the text.
Additional suggestions or comments can be provided below. If applicable, please indicate the page and line numbers from the draft report. | Thank you for the opportunity to serve as an expert reviewer for this comprehensive evidence-based review of the impact of the Mediterranean diet on health outcomes important to our nation's veterans. My comments follow. My principal concern is how predominantly findings from the Women's Health Initiative - Dietary Modification (WHI-DM) trial are featured throughout the document. I understand that the authors decided to adhere to the Cochrane definition of a Mediterranean diet and included studies that reported at least two of the following components:; - high monounsaturated/saturated fat ratio; - low to moderate red wine consumption; - high consumption of legumes; - high consumption of grains and cereals; - high consumption of fruits and vegetables; - low consumption of meat and meat products and increased consumption of fish; - moderate consumption of milk and dairy products; The WHI-DM intervention diet met this low bar of having 2 of the 7 components. However, the WHI-DM intervention diet was missing one of the key components - a high monounsaturated/saturated fat ratio. Several papers stress the importance of the inclusion of a source of monounsaturated fats in the Mediterranean diet. For example, see the following: http://www.ncbi.nlm.nih.gov/pmc/articles/PMC3916858/ The Mediterranean diet is a plant-based pattern, where vegetables, fruits, cereals (preferably as whole grain), legumes, and nuts should be consumed in high amount and frequency. The Mediterranean dietary pattern (MDP) also includes moderate consumption of fish and shellfish, white meat, eggs, and dairy products. On the contrary, consumption of red meat, processed meats, and foods rich in sugars and in fats should be small in both quantity and frequency. The principal source of dietary lipids of the MDP is olive oil and an adequate daily intake of water should be guaranteed, as well as moderate consumption of wine is recommended. And, http://www.ncbi.nlm.nih.gov/pmc/articles/PMC4222885/ The traditional Mediterranean diet is characterized by high consumption of vegetables, fruits and nuts, legumes, and unprocessed cereals; low consumption of meat and meat products; and low consumption of dairy products (with the exception of the long-preservable cheeses). Alcohol consumption was common in the traditional Mediterranean diet, but generally in moderation and in the form of wine and, as a rule, during meals- in the spirit of the ancient Greek word ‘symposium’. Total intake of lipids could be high (around or in excess of 40% of total energy intake, as in Greece), or moderate (around 30% of total energy intake, as in Italy) but, in all instances, the ratio of the beneficial monounsaturated to the non-beneficial saturated lipids is high, because of the high monounsaturated content of the liberally used olive oil. Finally, fish consumption has in the past been a function of the distance from the sea but has been, overall, at a moderate level. Including the WHI-DM as a randomized controlled clinical trial testing the efficacy of the Mediterranean diet seems like an immense leap when one of the key features of the WHI-DM intervention was a low-fat diet. See the NIH WHI website (https://www.nhlbi.nih.gov/whi/diet.htm) where it states that the dietary modification (DM) clinical trial component of the WHI studied the effect of a low-fat, high fruit, vegetable and grain diet on breast cancer, colorectal cancer and heart disease in postmenopausal women. Furthermore, the participants were counseled to decrease their fat intake to 20 percent of their total daily calories. This reviewer would like further justification for defining a Mediterranean diet as one that only includes two of the key components of the diet and most importantly prominently featuring the WHI-DM in the Executive Summary, Findings and Conclusions when it did not include one of the key, critical components of a Mediterranean diet; a high intake of monounsaturated fat. Please be clear throughout the manuscript that you are referring to type II diabetes mellitus and not “diabetes.” Page 31 - Table 2 Please explain how you defined consistency and precision in the studies. For example, in the first row of Table 2 you stated that “consistency is unknown and there was imprecision (PREDIMED).” What benchmark did you use to make this statement? Page 39 The statement “We evaluated strength of evidence for all-cause mortality finding insufficient evidence that mortality was similar between Mediterranean diet and control diet groups” is confusing. This could be interpreted to mean you found sufficient evidence that mortality was different between the Mediterranean diet and control diet groups. However, I don't think this was the intent of this statement. Page 42 - paragraph 3 The authors provide a good explanation of why the results are likely different between the PREDIMED studies and the WHI studies. This discussion should be prominent in the Executive Summary. Page 45 - Research Gaps - The authors refer to a “low fat diet” as another “healthy diet.” A diet low in total fat is no longer promoted by government and other important health organizations. For example the 2015 Dietary Guidelines Advisory Committee recommended dropping past recommendations to restrict total fat and rather emphasize the importance of reducing saturated fat and replace it with monounsaturated and polyunsaturated fats (see http://health.gov/dietaryguidelines/2015-scientific-report/pdfs/scientific-report-of-the-2015-dietary-guidelines-advisory-committee.pdf). Furthermore, the American Heart Association no longer promotes a “low-fat” diet but rather stresses the importance of including monounsaturated and polyunsaturated fats in a heart healthy diet (see http://www.heart.org/HEARTORG/GettingHealthy/NutritionCenter/HealthyEating/The-American-Heart-Associations-Diet-and-Lifestyle-Recommendations_UCM_305855_Article.jsp). Thus, I recommend not including a “low fat” diet as an example of a healthy diet. | As noted, the WHI-DM trial met our study inclusion criteria. We have clarified the dietary components in WHI-DM and noted how they differ from PREDIMED. We have clarified that the diabetes outcome was type 2 diabetes mellitus (T2DM) throughout the report. Page 31, Table 2. We have added definitions to the Strength of Evidence Tables. For the outcome noted, consistency is unknown because there is a single trial. The assessment of precision is based on the width of the confidence interval. The suggested thresholds for precision are 0.75 to 1.25 and the lower bound of the PREDIMED study was 0.71. Page 39. We have modified this statement. Page 42. Thank you for the suggestion. We have added this information to the Executive Summary. Page 45. Thank you for the suggestion. We have removed low fat diet from the statements about other healthy diets.
Additional suggestions or comments can be provided below. If applicable, please indicate the page and line numbers from the draft report. | 1. I would like to see more details about the subjects in the PREDIMED study (age, CVD risk factors, etc.). The number of subjects should be noted consistently (“7000 people” on page 3, line 44 and page 42, line 14 but “7447 people” on page 19, line 14).; 2. Why does the Strength of Evidence table (Executive Summary, page 7-8, and paragraph on page 30 and Table 2 on pages 31-32) NOT include cardiovascular incidence and mortality, with the other outcomes?; 3. The comments differentiating the PREDIMED study and the WHI study address the concerns raised by reviewers on the conference call earlier. | 1. We have added more details about the subjects and have made sure that we consistently report the number of subjects.; 2. Systematic reviews typically only assess Strength of Evidence for key outcomes. We focused on outcomes we considered most clinically relevant. We have added more information in the Methods section.; 3. Thank you.
Additional suggestions or comments can be provided below. If applicable, please indicate the page and line numbers from the draft report. | Pages 5 - 6; Key Findings and Strength of Evidence - 3rd bullet: As noted on the conference call, and in the complete results section of the ESP below, the intervention diet in this study was more similar to the control diet than the intervention diet in the PREDIMED trial! Suggest including this in the bullet in both this Summary section and the Summary section of the complete ESP. Page 6; Key Findings and Strength of Evidence - 6th bullet: Suggest the following edit to this bullet: “can be achieved in the setting of a controlled trial, but may require labor intensive behavioral interventions and monitoring.” Same comment applies to the corresponding sections in the complete ESP Page 6: Applicability: As noted in the Research Gaps section below, applicability of the available data to Veterans is limited by the presence of only 1 RCT in a comparable North American population and 1 RCT in an all-female population. Shouldn't this be included as a comment? Same comment applies to the corresponding sections in the complete ESP. Page 7: Executive Summary Table - Strength of Evidence. For Key Question #1, the Table is missing the evidence regarding reduction in CV events. Not sure why this key finding was not included in the Table. Same comment applies to the corresponding Table in the complete ESP. Page 43, 3rd Paragraph from bottom on Total Cancer Incidence and Mortality- ; Again, the fact that the WHI intervention diet is a very low intensity Mediterranean diet should be mentioned here as well. | Pages 5-6, Thank you. We have modified the Discussion/Conclusions section and this bullet has been eliminated. We emphasize differences between the trials. Page 6, We have modified the Discussion/Conclusions Section and eliminated the bullet points. We have included the suggested language. Page 6. Thank you. We have modified the Applicability section. Page 7. As noted above, systematic reviews typically only assess Strength of Evidence for key outcomes. We focused on outcomes we considered most clinically relevant. Page 43. Thank you. The WHI-DM diet is noted in this section.