# SEARCH STRATEGIES

## MEDLINE (OVID)

### Key Questions 1 and 2 Randomized Controlled Trials

1. exp Fruit/
2. fruit*.tw.
3. exp Vegetables/
4. Vegetable Proteins/
5. vegetable*.tw.
6. exp Fabaceae/
7. fabaceae.tw.
8. bean*.tw.
9. legume*.tw.
10. Lycopersicon esculentum/
11. lycopersicon esculent*.tw.
12. tomato*.tw.
13. solanum lycopersicum.tw.
14. Nuts/
15. (nut or nuts).tw.
16. Bread/
17. bread*.tw.
18. exp Cereals/
19. cereal*.tw.
20. grain*.tw.
21. Solanum tuberosum/
22. solanum tuberosum.tw.
23. potato*.tw.
24. Seeds/
25. (seed or seeds).tw.
26. olive oil.tw.
27. Fatty Acids, Monounsaturated/
28. monounsaturated fat*.tw.
29. mono-unsaturated fat*.tw.
30. exp Seafood/
31. exp Fish Oils/
32. fish.tw.
33. seafood*.tw.
34. shellfish.tw.
35. 1 or 2 or 3 or 4 or 5 or 6 or 7 or 8 or 9 or 10 or 11 or 12 or 13 or 14 or 15 or 16 or 17 or 18 or 19 or 20 or 21 or 22 or 23 or 24 or 25 or 26 or 27 or 28 or 29 or 30 or 31 or 32 or 33 or 34
36. ((high or more or increase* or elevat* or much or rais*) adj6 (intake or consumption or consume or eat* or amount*)).tw.
37. 35 and 36
38. exp Dairy Products/
39. exp Milk Proteins/
40. milk*.tw.
41. marg?rine*.tw.
42. butter*.tw.
43. dairy.tw.
44. cheese*.tw.
45. red meat*.tw.
46. processed meat*.tw.
47. yog?urt*.tw.
48. red wine*.tw.
49. 38 or 39 or 40 or 41 or 42 or 43 or 44 or 45 or 46 or 47 or 48
50. ((low or little or medium or moderate or less or decrease* or reduc* or restrict*) adj6 (intake or consumption or consume or eat* or amount*)).tw.
51. 49 and 50
52. Diet, Mediterranean/
53. (mediterranean adj3 diet*).tw.
54. (mediterranean adj6 food*).tw.
55. (mediterranean adj6 nutrition*).tw.
56. (mediterranean adj6 eat*).tw.
57. 52 or 53 or 54 or 55 or 56
58. 37 or 51 or 57
59. randomized controlled trial.pt.
60. controlled clinical trial.pt.
61. randomized.ab.
62. placebo.ab.
63. clinical trials as topic.sh.
64. randomly.ab.
65. trial.ti.
66. 59 or 60 or 61 or 62 or 63 or 64 or 65
67. 58 and 66
68. exp animal/ not humans.sh.
69. 67 not 68
70. limit 69 to (english language and yr = “1990 -Current”)
71. limit 70 to “all child (0 to 18 years)”
72. limit 71 to “all adult (19 plus years)”
73. 71 not 72
74. 70 not 73

### Key Questions 1 and 2 Cancer

1. exp Fruit/
2. fruit*.tw.
3. exp Vegetables/
4. Vegetable Proteins/
5. vegetable*.tw.
6. exp Fabaceae/
7. fabaceae.tw.
8. bean*.tw.
9. legume*.tw.
10. Lycopersicon esculentum/
11. lycopersicon esculent*.tw.
12. tomato*.tw.
13. solanum lycopersicum.tw.
14. Nuts/
15. (nut or nuts).tw.
16. Bread/
17. bread*.tw.
18. exp Cereals/
19. cereal*.tw.
20. grain*.tw.
21. Solanum tuberosum/
22. solanum tuberosum.tw.
23. potato*.tw.
24. Seeds/
25. (seed or seeds).tw.
26. olive oil.tw.
27. Fatty Acids, Monounsaturated/
28. monounsaturated fat*.tw.
29. mono-unsaturated fat*.tw.
30. exp Seafood/
31. exp Fish Oils/
32. fish.tw.
33. seafood*.tw.
34. shellfish.tw.
35. 1 or 2 or 3 or 4 or 5 or 6 or 7 or 8 or 9 or 10 or 11 or 12 or 13 or 14 or 15 or 16 or 17 or 18 or 19 or 20 or 21 or 22 or 23 or 24 or 25 or 26 or 27 or 28 or 29 or 30 or 31 or 32 or 33 or 34
36. ((high or more or increase* or elevat* or much or rais*) adj6 (intake or consumption or consume or eat* or amount*)).tw.
37. 35 and 36
38. exp Dairy Products/
39. exp Milk Proteins/
40. milk*.tw.
41. marg?rine*.tw.
42. butter*.tw.
43. dairy.tw.
44. cheese*.tw.
45. red meat*.tw.
46. processed meat*.tw.
47. yog?urt*.tw.
48. red wine*.tw.
49. 38 or 39 or 40 or 41 or 42 or 43 or 44 or 45 or 46 or 47 or 48
50. ((low or little or medium or moderate or less or decrease* or reduc* or restrict*) adj6 (intake or consumption or consume or eat* or amount*)).tw.
51. 49 and 50
52. Diet, Mediterranean/
53. (mediterranean adj3 diet*).tw.
54. (mediterranean adj6 food*).tw.
55. (mediterranean adj6 nutrition*).tw.
56. (mediterranean adj6 eat*).tw.
57. 52 or 53 or 54 or 55 or 56
58. 37 or 51 or 57
59. exp animal/ not humans.sh.
60. 58 not 59
61. limit 60 to (english language and yr = “1990 -Current”)
62. limit 61 to “all child (0 to 18 years)”
63. limit 62 to “all adult (19 plus years)”
64. 62 not 63
65. 61 not 64
66. cancer.mp. or Neoplasms/
67. 65 and 66

### Key Questions 1 and 2 Rheumatoid Arthritis

1. exp Fruit/
2. fruit*.tw.
3. exp Vegetables/
4. Vegetable Proteins/
5. vegetable*.tw.
6. exp Fabaceae/
7. fabaceae.tw.
8. bean*.tw.
9. legume*.tw.
10. Lycopersicon esculentum/
11. lycopersicon esculent*.tw.
12. tomato*.tw.
13. solanum lycopersicum.tw.
14. Nuts/
15. (nut or nuts).tw.
16. Bread/
17. bread*.tw.
18. exp Cereals/
19. cereal*.tw.
20. grain*.tw.
21. Solanum tuberosum/
22. solanum tuberosum.tw.
23. potato*.tw.
24. Seeds/
25. (seed or seeds).tw.
26. olive oil.tw.
27. Fatty Acids, Monounsaturated/
28. monounsaturated fat*.tw.
29. mono-unsaturated fat*.tw.
30. exp Seafood/
31. exp Fish Oils/
32. fish.tw.
33. seafood*.tw.
34. shellfish.tw.
35. 1 or 2 or 3 or 4 or 5 or 6 or 7 or 8 or 9 or 10 or 11 or 12 or 13 or 14 or 15 or 16 or 17 or 18 or 19 or 20 or 21 or 22 or 23 or 24 or 25 or 26 or 27 or 28 or 29 or 30 or 31 or 32 or 33 or 34
36. ((high or more or increase* or elevat* or much or rais*) adj6 (intake or consumption or consume or eat* or amount*)).tw.
37. 35 and 36
38. exp Dairy Products/
39. exp Milk Proteins/
40. milk*.tw.
41. marg?rine*.tw.
42. butter*.tw.
43. dairy.tw.
44. cheese*.tw.
45. red meat*.tw.
46. processed meat*.tw.
47. yog?urt*.tw.
48. red wine*.tw.
49. 38 or 39 or 40 or 41 or 42 or 43 or 44 or 45 or 46 or 47 or 48
50. ((low or little or medium or moderate or less or decrease* or reduc* or restrict*) adj6 (intake or consumption or consume or eat* or amount*)).tw.
51. 49 and 50
52. Diet, Mediterranean/
53. (mediterranean adj3 diet*).tw.
54. (mediterranean adj6 food*).tw.
55. (mediterranean adj6 nutrition*).tw.
56. (mediterranean adj6 eat*).tw.
57. 52 or 53 or 54 or 55 or 56
58. 37 or 51 or 57
59. exp animal/ not humans.sh.
60. 58 not 59
61. limit 60 to (english language and yr = “1990 -Current”)
62. limit 61 to “all child (0 to 18 years)”
63. limit 62 to “all adult (19 plus years)”
64. 62 not 63
65. 61 not 64
66. Arthritis, Rheumatoid/ or Arthritis/
67. 65 and 66

### Key Questions 1 and 2 Cognitive Function

1. exp Fruit/
2. fruit*.tw.
3. exp Vegetables/
4. Vegetable Proteins/
5. vegetable*.tw.
6. exp Fabaceae/
7. fabaceae.tw.
8. bean*.tw.
9. legume*.tw.
10. Lycopersicon esculentum/
11. lycopersicon esculent*.tw.
12. tomato*.tw.
13. solanum lycopersicum.tw.
14. Nuts/
15. (nut or nuts).tw.
16. Bread/
17. bread*.tw.
18. exp Cereals/
19. cereal*.tw.
20. grain*.tw.
21. Solanum tuberosum/
22. solanum tuberosum.tw.
23. potato*.tw.
24. Seeds/
25. (seed or seeds).tw.
26. olive oil.tw.
27. Fatty Acids, Monounsaturated/
28. monounsaturated fat*.tw.
29. mono-unsaturated fat*.tw.
30. exp Seafood/
31. exp Fish Oils/
32. fish.tw.
33. seafood*.tw.
34. shellfish.tw.
35. 1 or 2 or 3 or 4 or 5 or 6 or 7 or 8 or 9 or 10 or 11 or 12 or 13 or 14 or 15 or 16 or 17 or 18 or 19 or 20 or 21 or 22 or 23 or 24 or 25 or 26 or 27 or 28 or 29 or 30 or 31 or 32 or 33 or 34
36. ((high or more or increase* or elevat* or much or rais*) adj6 (intake or consumption or consume or eat* or amount*)).tw.
37. 35 and 36
38. exp Dairy Products/
39. exp Milk Proteins/
40. milk*.tw.
41. marg?rine*.tw.
42. butter*.tw.
43. dairy.tw.
44. cheese*.tw.
45. red meat*.tw.
46. processed meat*.tw.
47. yog?urt*.tw.
48. red wine*.tw.
49. 38 or 39 or 40 or 41 or 42 or 43 or 44 or 45 or 46 or 47 or 48
50. ((low or little or medium or moderate or less or decrease* or reduc* or restrict*) adj6 (intake or consumption or consume or eat* or amount*)).tw.
51. 49 and 50
52. Diet, Mediterranean/
53. (mediterranean adj3 diet*).tw.
54. (mediterranean adj6 food*).tw.
55. (mediterranean adj6 nutrition*).tw.
56. (mediterranean adj6 eat*).tw.
57. 52 or 53 or 54 or 55 or 56
58. 37 or 51 or 57
59. exp animal/ not humans.sh.
60. 58 not 59
61. limit 60 to (english language and yr = “1990 -Current”)
62. limit 61 to “all child (0 to 18 years)”
63. limit 62 to “all adult (19 plus years)”
64. 62 not 63
65. 61 not 64
66. Mild Cognitive Impairment/
67. Delirium, Dementia, Amnestic, Cognitive Disorders/ or Dementia/ or Dementia, Multi-Infarct/
68. Dementia/ or Alzheimer Disease/
69. 66 or 67 or 68
70. 65 and 69

### Key Question 3

1. exp Fruit/
2. fruit*.tw.
3. exp Vegetables/
4. Vegetable Proteins/
5. vegetable*.tw.
6. exp Fabaceae/
7. fabaceae.tw.
8. bean*.tw.
9. legume*.tw.
10. Lycopersicon esculentum/
11. lycopersicon esculent*.tw.
12. tomato*.tw.
13. solanum lycopersicum.tw.
14. Nuts/
15. (nut or nuts).tw.
16. Bread/
17. bread*.tw.
18. exp Cereals/
19. cereal*.tw.
20. grain*.tw.
21. Solanum tuberosum/
22. solanum tuberosum.tw.
23. potato*.tw.
24. Seeds/
25. (seed or seeds).tw.
26. olive oil.tw.
27. Fatty Acids, Monounsaturated/
28. monounsaturated fat*.tw.
29. mono-unsaturated fat*.tw.
30. exp Seafood/
31. exp Fish Oils/
32. fish.tw.
33. seafood*.tw.
34. shellfish.tw.
35. 1 or 2 or 3 or 4 or 5 or 6 or 7 or 8 or 9 or 10 or 11 or 12 or 13 or 14 or 15 or 16 or 17 or 18 or 19 or 20 or 21 or 22 or 23 or 24 or 25 or 26 or 27 or 28 or 29 or 30 or 31 or 32 or 33 or 34
36. ((high or more or increase* or elevat* or much or rais*) adj6 (intake or consumption or consume or eat* or amount*)).tw.
37. 35 and 36
38. exp Dairy Products/
39. exp Milk Proteins/
40. milk*.tw.
41. marg?rine*.tw.
42. butter*.tw.
43. dairy.tw.
44. cheese*.tw.
45. red meat*.tw.
46. processed meat*.tw.
47. yog?urt*.tw.
48. red wine*.tw.
49. 38 or 39 or 40 or 41 or 42 or 43 or 44 or 45 or 46 or 47 or 48
50. ((low or little or medium or moderate or less or decrease* or reduc* or restrict*) adj6 (intake or consumption or consume or eat* or amount*)).tw.
51. 49 and 50
52. Diet, Mediterranean/
53. (mediterranean adj3 diet*).tw.
54. (mediterranean adj6 food*).tw.
55. (mediterranean adj6 nutrition*).tw.
56. (mediterranean adj6 eat*).tw.
57. 52 or 53 or 54 or 55 or 56
58. 37 or 51 or 57
59. exp animal/ not humans.sh.
60. 58 not 59
61. limit 60 to (english language and yr = “1990 -Current”)
62. limit 61 to “all child (0 to 18 years)”
63. limit 62 to “all adult (19 plus years)”
64. 62 not 63
65. 61 not 64
66. adherence.mp.
67. 65 and 66
68. Patient Compliance/
69. 66 or 68
70. 65 and 69

## COCHRANE

### Key Questions 1 and 2 Randomized Controlled Trials

1. fruit or vegetable or legume or nut? or bread or cereal or grain or (olive next oil) or (monounsaturated next fat) or (mono unsaturated next fat) or fish
2. (fruit or vegetable or nuts or bread or cereals or fatty acids, monounsaturated or seafood):kw
3. ((high or more or increase or elevat or much or rais) near (intake or consumption or consume or eat or amount))
4. (#1 or #2) and #3
5. red next meat or red next wine
6. MeSH descriptor: [Dairy Products] explode all trees
7. ((low or little or medium or moderate or less or decrease or reduc or restrict) near (intake or consumption or consume or eat or amount))
8. (#5 or #6) and #7
9. mediterranean near diet
10. MeSH descriptor: [Diet, Mediterranean] explode all trees
11. #4 or #8 or #10 (Publication year from 1990 to 2015)

### Key Questions 1 and 2 Cancer

1. fruit or vegetable or legume or nut? or bread or cereal or grain or (olive next oil) or (monounsaturated next fat) or (mono unsaturated next fat) or fish
2. (fruit or vegetable or nuts or bread or cereals or fatty acids, monounsaturated or seafood):kw
3. ((high or more or increase or elevat or much or rais) near (intake or consumption or consume or eat or amount))
4. (#1 or #2) and #3
5. red next meat or red next wine
6. MeSH descriptor: [Dairy Products] explode all trees
7. ((low or little or medium or moderate or less or decrease or reduc or restrict) near (intake or consumption or consume or eat or amount))
8. (#5 or #6) and #7
9. mediterranean near diet
10. MeSH descriptor: [Diet, Mediterranean] explode all trees
11. #4 or #8 or #10 (Publication year from 1990 to 2015)
12. Cancer
13. MeSH descriptor: [Neoplasms] explode all trees
14. #12 or #13
15. #14 and #11

### Key Questions 1 and 2 Rheumatoid Arthritis

1. fruit or vegetable or legume or nut? or bread or cereal or grain or (olive next oil) or (monounsaturated next fat) or (mono unsaturated next fat) or fish
2. (fruit or vegetable or nuts or bread or cereals or fatty acids, monounsaturated or seafood):kw
3. ((high or more or increase or elevat or much or rais) near (intake or consumption or consume or eat or amount))
4. (#1 or #2) and #3
5. red next meat or red next wine
6. MeSH descriptor: [Dairy Products] explode all trees
7. ((low or little or medium or moderate or less or decrease or reduc or restrict) near (intake or consumption or consume or eat or amount))
8. (#5 or #6) and #7
9. mediterranean near diet
10. MeSH descriptor: [Diet, Mediterranean] explode all trees
11. #4 or #8 or #10 (Publication year from 1990 to 2015)
12. MeSH descriptor: [Arthritis, Rheumatoid] explode all trees
13. #11 and #12

### Key Questions 1 and 2 Cognitive Function

1. fruit or vegetable or legume or nut? or bread or cereal or grain or (olive next oil) or (monounsaturated next fat) or (mono unsaturated next fat) or fish
2. (fruit or vegetable or nuts or bread or cereals or fatty acids, monounsaturated or seafood):kw
3. ((high or more or increase or elevat or much or rais) near (intake or consumption or consume or eat or amount))
4. (#1 or #2) and #3
5. red next meat or red next wine
6. MeSH descriptor: [Dairy Products] explode all trees
7. ((low or little or medium or moderate or less or decrease or reduc or restrict) near (intake or consumption or consume or eat or amount))
8. (#5 or #6) and #7
9. mediterranean near diet
10. MeSH descriptor: [Diet, Mediterranean] explode all trees
11. #4 or #8 or #10 (Publication year from 1990 to 2015)
12. Mild cognitive impairment
13. MeSH descriptor: [Dementia] explode all trees
14. MeSH descriptor: [Alzheimer Disease] explode all trees
15. #12 or #13 or #14
16. #15 or #11

### Key Question 3

1. fruit or vegetable or legume or nut? or bread or cereal or grain or (olive next oil) or (monounsaturated next fat) or (mono unsaturated next fat) or fish
2. (fruit or vegetable or nuts or bread or cereals or fatty acids, monounsaturated or seafood):kw
3. ((high or more or increase or elevat or much or rais) near (intake or consumption or consume or eat or amount))
4. (#1 or #2) and #3
5. red next meat or red next wine
6. MeSH descriptor: [Dairy Products] explode all trees
7. ((low or little or medium or moderate or less or decrease or reduc or restrict) near (intake or consumption or consume or eat or amount))
8. (#5 or #6) and #7
9. mediterranean near diet
10. MeSH descriptor: [Diet, Mediterranean] explode all trees
11. #4 or #8 or #10 (Publication year from 1990 to 2015)
12. Adherence
13. MeSH descriptor: [Patient Compliance] explode all trees
14. #12 or #13
15. #11 or #14

## CINAHL

### Key Questions 1 and 2 Randomized Controlled Trials

1. Fruit* vegetable* legume* nut nuts bread breads cereal* “olive oil” “monounsaturared fat*” “mono-unsaturated fat*” fish
2. (MH “Fruit+”) OR (MH “Vegetables+”) OR (MH “Legumes+”) OR (MH “Nuts+”) OR (MH “BREAD”) OR (MH “Cereals+”) OR (MH “Olive Oil”) OR (MH “Fatty Acids, Monounsaturated+”) OR (MH “Seafood+”)
3. High more increase elevat* much rais*
4. Intake consumption consume eat* amount*
5. 3 AND 4
6. 1 OR 2
7. 5 AND 6
8. “red meat*” “red wine*”
9. (MH “Dairy Products+”)
10. Low little medium moderate less decreas* reduc* restrict*
11. 4 AND 10
12. 8 OR 9
13. 11 AND 12
14. (MH “Mediterranean Diet”)
15. 7 OR 13 OR 14 (published date: 19900101-2015; English Language; Exclude MEDLINE records; Human; Age Groups: All Adult)

### Key Questions 1 and 2 Cancer

1. Fruit* vegetable* legume* nut nuts bread breads cereal* “olive oil” “monounsaturared fat*” “mono-unsaturated fat*” fish
2. (MH “Fruit+”) OR (MH “Vegetables+”) OR (MH “Legumes+”) OR (MH “Nuts+”) OR (MH “BREAD”) OR (MH “Cereals+”) OR (MH “Olive Oil”) OR (MH “Fatty Acids, Monounsaturated+”) OR (MH “Seafood+”)
3. High more increase elevat* much rais*
4. Intake consumption consume eat* amount*
5. 3 AND 4
6. 1 OR 2
7. 5 AND 6
8. “red meat*” “red wine*”
9. (MH “Dairy Products+”)
10. Low little medium moderate less decreas* reduc* restrict*
11. 4 AND 10
12. 8 OR 9
13. 11 AND 12
14. (MH “Mediterranean Diet”)
15. 7 OR 13 OR 14 (published date: 19900101-2015; English Language; Exclude MEDLINE records; Human; Age Groups: All Adult)
16. Cancer
17. 15 AND 16

### Key Questions 1 and 2 Rheumatoid Arthritis

1. Fruit* vegetable* legume* nut nuts bread breads cereal* “olive oil” “monounsaturared fat*” “mono-unsaturated fat*” fish
2. (MH “Fruit+”) OR (MH “Vegetables+”) OR (MH “Legumes+”) OR (MH “Nuts+”) OR (MH “BREAD”) OR (MH “Cereals+”) OR (MH “Olive Oil”) OR (MH “Fatty Acids, Monounsaturated+”) OR (MH “Seafood+”)
3. High more increase elevat* much rais*
4. Intake consumption consume eat* amount*
5. 3 AND 4
6. 1 OR 2
7. 5 AND 6
8. “red meat*” “red wine*”
9. (MH “Dairy Products+”)
10. Low little medium moderate less decreas* reduc* restrict*
11. 4 AND 10
12. 8 OR 9
13. 11 AND 12
14. (MH “Mediterranean Diet”)
15. 7 OR 13 OR 14 (published date: 19900101-2015; English Language; Exclude MEDLINE records; Human; Age Groups: All Adult)
16. Rheumatoid arthritis
17. Arthritis
18. 16 OR 17
19. 15 AND 18

### Key Questions 1 and 2 Cognitive Function

1. Fruit* vegetable* legume* nut nuts bread breads cereal* “olive oil” “monounsaturared fat*” “mono-unsaturated fat*” fish
2. (MH “Fruit+”) OR (MH “Vegetables+”) OR (MH “Legumes+”) OR (MH “Nuts+”) OR (MH “BREAD”) OR (MH “Cereals+”) OR (MH “Olive Oil”) OR (MH “Fatty Acids, Monounsaturated+”) OR (MH “Seafood+”)
3. High more increase elevat* much rais*
4. Intake consumption consume eat* amount*
5. 3 AND 4
6. 1 OR 2
7. 5 AND 6
8. “red meat*” “red wine*”
9. (MH “Dairy Products+”)
10. Low little medium moderate less decreas* reduc* restrict*
11. 4 AND 10
12. 8 OR 9
13. 11 AND 12
14. (MH “Mediterranean Diet”)
15. 7 OR 13 OR 14 (published date: 19900101-2015; English Language; Exclude MEDLINE records; Human; Age Groups: All Adult)
16. Mild cognitive impairment
17. Dementia
18. Alzheimer disease
19. 16 OR 17 OR 18
20. 15 AND 19

### Key Question 3

1. Fruit* vegetable* legume* nut nuts bread breads cereal* “olive oil” “monounsaturared fat*” “mono-unsaturated fat*” fish
2. (MH “Fruit+”) OR (MH “Vegetables+”) OR (MH “Legumes+”) OR (MH “Nuts+”) OR (MH “BREAD”) OR (MH “Cereals+”) OR (MH “Olive Oil”) OR (MH “Fatty Acids, Monounsaturated+”) OR (MH “Seafood+”)
3. High more increase elevat* much rais*
4. Intake consumption consume eat* amount*
5. 3 AND 4
6. 1 OR 2
7. 5 AND 6
8. “red meat*” “red wine*”
9. (MH “Dairy Products+”)
10. Low little medium moderate less decreas* reduc* restrict*
11. 4 AND 10
12. 8 OR 9
13. 11 AND 12
14. (MH “Mediterranean Diet”)
15. 7 OR 13 OR 14 (published date: 19900101-2015; English Language; Exclude MEDLINE records; Human; Age Groups: All Adult)
16. Adherence
17. 15 AND 16