# SUMMARY AND DISCUSSION

SMAs have the potential to offer chronic disease care that is more efficient while improving staff satisfaction and patient outcomes. We identified 15 RCTs and 4 observational studies of varying quality comparing SMAs with usual care or enhanced usual care. Studies were conducted exclusively in patients with diabetes or in older adults with higher than average medical utilization. No eligible studies enrolled patients with the other chronic conditions of interest: coronary artery disease, chronic heart failure, asthma, chronic obstructive pulmonary disease, hyperlipidemia, or hypertension. This limited diversity in patient populations compromised our ability to determine if effects varied by condition. However, the included studies reported outcomes ranging from patient experience to biophysical and economic outcomes. These findings and the overall strength of evidence are summarized and discussed by key question.

## SUMMARY OF EVIDENCE BY KEY QUESTION

### Key Question 1

Few studies (0 to 3) reported effects on staff experience, patient experience, or treatment adherence. The strength of evidence for each of these outcomes was judged to be insufficient to estimate an effect of the SMA intervention in both patients with diabetes and older adults.

The most robust finding of this evidence synthesis is that SMAs for patients with diabetes appear to have a significant impact on biophysical outcomes. Hemoglobin A1c improved by approximately 0.6 percentage points, and systolic blood pressure by about 5 mmHg; both these findings were statistically significant. LDL-C improved by approximately 7 mg/dl, but this was not statistically significant. While each individual finding is only moderately robust given the limitations in study quality and unexplained variability in intervention effects, the constellation of findings taken together indicates that SMAs help intermediate clinical outcomes for type 2 diabetes. Similar outcomes were not reported in older adults.

For patients with diabetes, there was significant improvement on HRQOL, measured in 3 of 4 studies with a relatively sensitive, disease-specific, quality-of-life scale. Positive effects on HRQOL were found in one trial conducted in older adults, but functional status was not affected in these studies. Studies in older adults show a pattern of lower health care utilization, but the number of studies and participants are relatively few and these results should be considered preliminary. In patients with diabetes, lower hospitalization was the most consistent effect, but effects on other economic outcomes were too preliminary to estimate an effect. Our judgments about the strength of evidence (SOE) prioritized data from RCTs.

Table 5 Summary of the intervention effects and SOE for KQ 1

Population | Number of Studies^a^ (Subjects) | Domains Pertaining to SOE | | | | SOE
Population | Number of Studies^a^ (Subjects)
Population | Number of Studies^a^ (Subjects) | Risk of Bias: Study Design/Quality | Consistency | Directness | Precision | Effect Estimate (95% CI)
Staff experience | | | | | | Insufficient
Diabetes | 0 | NA | NA | NA | NA | Not estimable
Older adults | 1 (1236) | Obs/Fair | NA | Direct | Imprecise | Not estimable
Patient experience | | | | | | Insufficient
Diabetes | 2 (769) | RCT/Fair | Consistent | Direct | Imprecise | No effect
Older adults | 2 (444) | RCT/Fair | Inconsistent | Direct | Imprecise | Small to large positive effect
Treatment adherence | | | | | | Insufficient
Diabetes | 3 (536) | RCT/Fair | Some inconsistency | Direct | Imprecise | Not estimable
Older adults | 0 | NA | NA | NA | NA | Not estimable
Biophysical
Diabetes: A1c | 13 (2921) | RCT/Good | Inconsistent | Direct | Some imprecision | MD = −0.55 (−0.99 to −0.11) Moderate SOE
Diabetes:
Total Cholesterol | 5 (1556) | RCT/Fair | Inconsistent | Direct | Imprecise | MD = −4.9 (−17.8 to 7.9) Low SOE
LDL Cholesterol | 5 (997) | RCT/Fair | Inconsistent | Direct | Imprecise | MD −6.6 (−16.1 to 2.8) Low SOE
Diabetes: Blood pressure | 5 (1125) | RCT/Good | Consistent | Direct | Some imprecision | MD = −5.2 (−7.4 to −3.1) Moderate SOE
Older adults | 0 | NA | NA | NA | NA | Not estimable
Health-related quality of life or functional status
Diabetes | 5 (1561) | RCT/Fair | Inconsistent | Direct | Imprecise | SMD = −0.84 (−1.6 to −0.03) Low SOE
Older adults | 2 (615) | RCT/Fair | Inconsistent | Direct | Imprecise | Not estimable
Economic
Diabetes | 5 (1339) | RCT/Good | Inconsistent | Direct | Imprecise | ED visits lower rates in 2 of 5 studies Insufficient SOE
Diabetes | 5 (1339) | RCT/Good | Consistent | Direct | Some imprecision | Hospitalizations lower in 4 of 5 studies Low SOE
Diabetes | 4 (1125) | RCT/Fair | Inconsistent | Direct | Imprecise | Total costs range from lower to higher Insufficient SOE
Older adults | 2 (615) | RCT/Fair | Consistent | Direct | Imprecise | ED visits lower rates in 2 of 2 studies Low SOE
Older adults | 2 (615) | RCT/Fair | Some inconsistency | Direct | Imprecise | Hospitalizations lower in 1 of 2 studies Insufficient SOE
Older adults | 2 (615) | RCT/Fair | Inconsistent | Direct | Imprecise | Total costs lower but not statistically significant Insufficient SOE

a Studies (subjects) given are for randomized trials; observational studies were also considered in SOE ratings but are not listed separately in the table.

Abbreviations: CI=confidence interval; ED=emergency department; MD=mean difference; NA=not applicable; RCT=randomized controlled trial; RD=risk difference; RR=risk ratio; SMD=standardized mean difference; SOE=strength of evidence

### Key Questions 2 and 3

No studies explored KQ 2 (identifying the subgroups of patients that would benefit most from an SMA intervention) or KQ 3 (identifying the specific components of an SMA intervention that were most potent). We devised a robustness score to attempt to address KQ 3, but it was not able to discriminate degrees of effectiveness among intervention components. More than 70 percent of all studies were similar on six of the seven variables used in the robustness score: (1) whether the team was continuous, (2) whether the group was closed, (3) whether individual breakout sessions were conducted, (4) whether medication changes were made, (5) how long each session was, and (6) whether there was contact outside the session. It is possible that there are other more important variables that are not being measured with current approaches. The strength of evidence for both questions was judged to be insufficient.

## CLINICAL AND POLICY IMPLICATIONS

A key finding is that SMAs have been evaluated primarily in patients with diabetes, and to a lesser extent and with a narrow range of outcomes for older adults with high utilization. Even where the data are more robust in those with diabetes, it is challenging to place into context the improvements seen in biophysical parameters with SMAs. However, we can discuss the clinical importance of these findings in at least two ways. First, we can compare the results to clinical trial data relative to starting any agent for these conditions. The improvement seen in one year on systolic blood pressure across all arms of the Antihypertensive and Lipid-Lowering Treatment to Prevent Heart Attack Trial (ALLHAT), trial, after adding the chosen first medication, was approximately 6.6 mmHg; patients in SMAs achieved approximately 75 percent of that level of improvement.38 Similarly, adding a first-line oral hypoglycemic agent at a maximally tolerated dose usually lowers A1c by 1 to 1.5 percentage points;38 patients in SMAs achieve 33 to 50 percent of that goal. The change in LDL-C of 7 mg/dl is much smaller compared with drug effect, approximately 15 percent of what would be expected with clinical trial doses of an HMG-CoA reductase inhibitor (“statin”). However, each drug comparison is made relative to placebo controls. For SMA interventions, the comparator is usual care, which typically includes medication treatment, and thus one would expect the effects to be smaller.

Another way to evaluate the improvements observed with SMA is against the known standard deviations for the outcomes in the population of patients with disease, and then calculate effect sizes. While many different values for standard deviations for the relevant parameters are reported in the literature, effect sizes of SMA interventions for systolic BP, A1c, and LDL-C are approximately 0.5, 0.33, and 0.25, respectively. These are considered moderate to small effect sizes, but all would be considered important.39

The improvements in A1c and blood pressure, and the more modest improvement in LDL-C are possibly synergistic, or at least additive, in prevention of the macrovascular and microvascular complications of diabetes.40 Thus, as a whole, SMAs may impact the risk of complications among patients with diabetes. Even if half the effect were lost in translation due to lower treatment fidelity when implemented outside of clinical trials, there would still likely be an important improvement in complication risk for patients enrolled in a diabetes SMA intervention. However, it is important to remember that the degree of synergy in the context of improvements in multiple outcomes is guesswork at best; SMAs—and indeed multicomponent health services in general—have not been studied with enough patients to determine their actual effects on major cardiovascular or microvascular complications.

Finally, many authors propose that SMAs are more satisfying than standard outpatient visits for both patients and providers, but few have measured patient and staff satisfaction. Because SMAs are a major shift in clinic organization, more data are needed on these variables as well as cost-to- benefit ratios before a general policy recommendation can be made.

### Generalizability of Findings

The results of the diabetes studies have limitations to their external validity. Using the PICOTS framework (population, intervention, comparator, outcome, timing, setting), the applicability of the findings appears strong with respect to (1) population because a reasonable balance of race and sex was achieved among patients, (2) outcomes because there is general consensus that A1c, blood pressure, and LDL-C are the important outcomes in diabetes, and (3) timeframes because there is general consensus that improvement of 6 months or longer is clinically relevant. However, none of the studies examined maintenance of effect after the intervention ended. Although similar in many aspects, there were enough differences in intervention process that a conclusion as to what makes an SMA intervention particularly successful could not be drawn. In addition, what constituted usual care was inconsistently defined. Therefore, intervention heterogeneity and the types of usual care comparators, may also be important limitations to the generalizability of our results.

The heterogeneity of the studies is concerning. Complex health services interventions are often a black box; that is, they contain many components that are hard to capture and tease out even in a well-conducted analysis. If there was a particular aspect of these interventions that was critical to predicting improved clinical outcomes, we were unable to capture that with the available data. This raises the question of a possible uncaptured element of SMAs that is important for potency, effectiveness, or generalizability. Without further, more mechanistic studies that attempt to elucidate the key components of an SMA intervention, implementation of a diabetes SMA or design of an SMA for another condition will be at least partially based on reasoned judgment rather than strict evidence-based decision making.

An additional concern is that none of these studies was conducted in “real world” settings. All of the diabetes studies were conducted in academic, government, or vertically integrated systems. There are two potential reasons for this. First, all complex chronic care redesign interventions are easier to implement in systems that are either highly controlled or in which there is interest in research. Second, SMAs are difficult to implement in fee-for-service, independent clinics because they are unlikely to derive any financial benefits from improved quality of care but would have to absorb the cost in time and money of implementing the SMA. It is possible that this barrier could be relieved by Accountable Care Organizations, but this theory is still untested. Lastly, academic, government, or vertically integrated systems may also have very high quality usual care. While factors related to setting may not negatively impact the generalizability of these results for implementation of diabetes or other SMAs within vertically integrated systems such as the VA, they do suggest caution when considering the use of SMAs outside such systems.

### Should SMAs Be Implemented?

The clearest finding of this evidence synthesis is that the existing knowledge base does not provide enough evidence to make a strictly evidence-driven decision about implementation of SMAs in any context except diabetes. Regarding diabetes SMA implementation, this evidence synthesis raises several key issues summarized in Table 6.

Table 6 Implementation issues

Issue for Implementation of Diabetes SMAs | Potential Solution
Enrollment There was no clear indication of which patients will receive the most benefit from this alternative structure. | Allow selection criteria for SMAs to fit specific local needs.
Elements of intervention There was no clear indication of which elements were most effective. | Use the most prevalent common elements: Prescribing clinician A consistent clinical lead for the SMA group At least 3 team members Closed group participants Individual time with clinician (brief) Medications evaluated Group duration of 90 to 120 minutes Variable elements that could be tailored to clinic or patient population: Group size Participation of family and friends Contact with participants outside of group
Potential mechanisms of intervention Very few studies reported any intermediate or mechanistic outcomes such as self-management, medication change, or access to care. | Measure these at implementation; use Plan-Do-Study-Act approach to allow these factors to change intervention over time.
Infrastructure changes There was no clear indication whether the change in clinic structure was more effective or efficient. | In already vertically integrated settings, such as VA, these changes are not as difficult. The broad-based improvement seen was clinically meaningful balanced against satisfaction and cost, especially for older adults.

SMAs also have costs. These costs are not just the labor cost of redirecting providers away from their existing clinical responsibilities to conduct an SMA; there is also the time and labor cost to establish a new structure for care. This lack of information about both direct costs and changes in utilization in all but older adults who are high utilizers of the health care system is a key gap in the existing literature. For those patients, hospital admissions, ER visits and total costs were consistently lower with SMAs. Also, implementation of SMAs will not succeed if either patients or providers are unsatisfied with the new structure, and effects on patient and staff experience remain largely unknown, again with the exception of older adults who expressed increased satisfaction with SMAs.

## STRENGTHS AND LIMITATIONS

Our study has a number of strengths, including a protocol-driven review, a comprehensive search, careful quality assessment, and rigorous quantitative synthesis methods. Our report, and the literature, also has limitations. An important limitation is the lack of breadth to the types of patients and illnesses that have been studied in the context of an SMA. The evidence synthesis found no explicit data regarding system-level, as opposed to patient-level, benefits of SMAs; the fact that as many studies viewed the SMA as an add-on to, rather than a replacement for, usual primary care suggests that improvements in access may not be as great as desired. In addition, the components of the interventions were often not described adequately for replication, especially the content of the group education time. Finally, outcomes reported varied substantially across studies and our attempts to explain the observed variability in intervention effects were unsuccessful. With unexplained variability, summary measures of treatment effect may not adequately describe the expected effects of the intervention.

## RECOMMENDATIONS FOR FUTURE RESEARCH

We used the framework recommended Robinson et al.41 to identify gaps in evidence and classify why these gaps exist (Table 7). The next generation of research in SMAs for patients with diabetes and other conditions should close the gaps outlined in the previous section.

Table 7 Evidence gaps and future research

Evidence Gap | Reason | Type of Studies to Consider
Patients
Absence of data for patients with conditions other than diabetes mellitus and high utilization | Insufficient information | Single and multisite RCTs Quasi-experimental studies
Interventions
Uncertain which elements of an SMA intervention are most effective and efficient | Insufficient information | RCTs of head-to-head comparisons of different types of SMAs; Disaggregation trials
Outcomes
Uncertain effects on patient and staff satisfaction | Insufficient information | Nonrandomized or cluster randomized, multisite implementation studies, qualitative studies
Uncertain effects on physiological variables other than HbA1c | Insufficient information | Large scale RCTs Nonrandomized, cluster controlled trials, controlled before-and-after studies, interrupted time series
Uncertain effects on health system costs with the exception of the elderly high utilizers of the health system | Insufficient information | Costs analyses
Uncertain whether there would be unintended consequences to other aspects of the health care system if SMAs were implemented | Insufficient information | Multisite observational studies

Abbreviation: RCT=randomized controlled trial

Our review shows that SMAs, typically using closed panels with individual breakouts and the opportunity for medication management, help intermediate clinical outcomes for type 2 diabetes. A smaller literature shows positive effects on patient experience in older adults and the possibility of lower health care utilization. SMAs may be most effective for illnesses such as diabetes that have a phase in which the risk of complication is relatively high while the disease is simultaneously asymptomatic, and in which medication titration and self-management are important. Until further studies are done that allow for comparisons across conditions, the targeting of SMA for chronic conditions other than diabetes will remain speculative. Finally, repeating the existing diabetes SMA efficacy trials in fee-for-service settings would be important to understand the extent to which SMAs work when the profit motive is essential to the practice model.