# REFERENCES

1 Fletcher RD, Amdur RL, Kolodner R, et al. Blood Pressure Control Among US Veterans: A Large Multi-Year Analysis of Blood Pressure Data from the VA Health Data Repository. Circulation. 2012.
2 King H, Aubert RE, Herman WH. Global burden of diabetes, 1995–2025: prevalence, numerical estimates, and projections. Diabetes Care. 1998;21(9):1414-31. [pmid: 9727886].
3 Edelman D, Fredrickson SK, Melnyk SD, et al. Medical clinics versus usual care for patients with both diabetes and hypertension: a randomized trial. Ann Intern Med. 2010;152(11):689-96. [pmid: 20513826].
4 Jaber R, Braksmajer A, Trilling JS. Group visits: A qualitative review of current research. Journal of the American Board of Family Medicine. 2006;19(3):276-290. [pmid: 16672681].
5 Kirsh S, Watts S, Pascuzzi K, et al. Shared medical appointments based on the chronic care model: a quality improvement project to address the challenges of patients with diabetes with high cardiovascular risk. Qual Saf Health Care. 2007;16(5):349-53. [pmid: 17913775].
6 Noffsinger E. Increasing quality care and access while reducing cost through drop-in group medical appointments (DIGMAs). Group Pract J. 1999;48(1):12-18.
7 Riley SB, Marshall ES. Group visits in diabetes care: a systematic review. Diabetes Educ. 2010;36(6):936-44. [pmid: 20974905].
8 Taveira TH, Friedmann PD, Cohen LB, et al. Pharmacist-led group medical appointment model in type 2 diabetes. Diabetes Educ. 2010;36(1):109-17. [pmid: 19966072].
9 Beck A, Scott J, Williams P, et al. A randomized trial of group outpatient visits for chronically ill older HMO members: the Cooperative Health Care Clinic. J Am Geriatr Soc. 1997;45(5):543-9. [pmid: 9158573].
10 Levine MD, Ross TR, Balderson BH, et al. Implementing group medical visits for older adults at group health cooperative. J Am Geriatr Soc. 2010;58(1):168-72. [pmid: 20002506].
11 Scott JC, Conner DA, Venohr I, et al. Effectiveness of a group outpatient visit model for chronically ill older health maintenance organization members: a 2-year randomized trial of the cooperative health care clinic. J Am Geriatr Soc. 2004;52(9):1463-70. [pmid: 15341547].
12 Coleman EA, Eilertsen TB, Kramer AM, et al. Reducing emergency visits in older adults with chronic illness. A randomized, controlled trial of group visits. Eff Clin Pract. 2001;4(2):49-57. [pmid: 11329985].
13 Bray P, Thompson D, Wynn JD, et al. Confronting disparities in diabetes care: the clinical effectiveness of redesigning care management for minority patients in rural primary care practices. J Rural Health. 2005;21(4):317-21. [pmid: 16294654].
14 Clancy DE, Cope DW, Magruder KM, et al. Evaluating concordance to American Diabetes Association standards of care for type 2 diabetes through group visits in an uninsured or inadequately insured patient population. Diabetes Care. 2003;26(7):2032-6. [pmid: 12832308].
15 Clancy DE, Huang P, Okonofua E, et al. Group visits: promoting adherence to diabetes guidelines. J Gen Intern Med. 2007;22(5):620-4. [pmid: 17443369].
16 Culhane-Pera K, Peterson KA, Crain AL, et al. Group visits for Hmong adults with type 2 diabetes mellitus: a pre-post analysis. J Health Care Poor Underserved. 2005;16(2):315-27. [pmid: 15937395].
17 Gutierrez N, Gimple NE, Dallo FJ, et al. Shared medical appointments in a residency clinic: an exploratory study among Hispanics with diabetes. Am J Manag Care. 2011;17(6 Spec No):e212-4. [pmid: 21756014].
18 Naik AD, Palmer N, Petersen NJ, et al. Comparative effectiveness of goal setting in diabetes mellitus group clinics: randomized clinical trial. Arch Intern Med. 2011;171(5):453-9. [pmid: 21403042].
19 Sadur CN, Moline N, Costa M, et al. Diabetes management in a health maintenance organization. Efficacy of care management using cluster visits. Diabetes Care. 1999;22(12):2011-7. [pmid: 10587835].
20 Trento M, Passera P, Tomalino M, et al. Group visits improve metabolic control in type 2 diabetes: a 2-year follow-up. Diabetes Care. 2001;24(6):995-1000. [pmid: 11375359].
21 Trento M, Passera P, Borgo E, et al. A 3-year prospective randomized controlled clinical trial of group care in type 1 diabetes. Nutr Metab Cardiovasc Dis. 2005;15(4):293-301. [pmid: 16054554].
22 Trento M, Gamba S, Gentile L, et al. Rethink Organization to iMprove Education and Outcomes (ROMEO): a multicenter randomized trial of lifestyle intervention by group care to manage type 2 diabetes. Diabetes Care. 2010;33(4):745-7. [pmid: 20103547].
23 Krzywkowski-Mohn SM. Diabetic control and patient perception of the scheduled in group medical appointment at the Cincinnati Veterans Administration Medical Center. ProQuest Information & Learning. 2009.
24 Moher D, Liberati A, Tetzlaff J, et al. Preferred reporting items for systematic reviews and meta-analyses: the PRISMA statement. PLoS Med. 2009;6(7):e1000097. [pmid: 19621072].
25 Wilczynski NL, McKibbon KA, Haynes RB. Response to Glanville et al.: How to identify randomized controlled trials in MEDLINE: ten years on. J Med Libr Assoc. 2007;95(2):117-8. author reply 119–20. [pmid: 17443240].
26 Taveira TH, Dooley AG, Cohen LB, et al. Pharmacist-led group medical appointments for the management of type 2 diabetes with comorbid depression in older adults. Ann Pharmacother. 2011;45(11):1346-55. [pmid: 22028418].
27 Loney-Hutchinson LM, Provilus AD, Jean-Louis G, et al. Group visits in the management of diabetes and hypertension: effect on glycemic and blood pressure control. Current Diabetes Reports. 2009;9(3):238-242. [pmid: 19490826].
28 Kirsh SR, Aron DC. Integrating the chronic-care model and the ACGME competencies: using shared medical appointments to focus on systems-based practice... Accreditation Council for Graduate Medical Education. Quality & Safety in Health Care. 2008;17(1):15-19. [pmid: 18245214].
29 Agency for Healthcare Research and Quality. Methods Guide for Effectiveness and Comparative Effectiveness Reviews. Rockville, MD. Agency for Healthcare Research and Quality. Available at: http://www.effectivehealthcare.ahrq.gov/index.cfm/search-for-guidesreviews-and-reports/?pageaction=displayproduct&productid=318. Accessed May 10, 2012.
30 Viswanathan M, Berkman ND. Development of the RTI Item Bank on Risk of Bias and Precision of Observational Studies, Methods Research Report. (Prepared by the RTI International-University of North Carolina Evidence-based Practice Center under Contract No. 290-2007-0056-I) AHRQ Publication No 11-EHC028-EF. Rockville, MD. Agency for Healthcare Research and Quality. Available at: http://www.effectivehealthcare.ahrq.gov/ehc/products/350/784/RTI-Risk-of-Bias_Final-Report_20110916.pdf. Accessed May 15, 2012.
31 Higgins JP, Thompson SG. Quantifying heterogeneity in a meta-analysis. Stat Med. 2002;21(11):1539-58. [pmid: 12111919].
32 Guyatt GH, Oxman AD, Kunz R, et al. GRADE guidelines 6. Rating the quality of evidence--imprecision. J Clin Epidemiol. 2011;64(12):1283-93. [pmid: 21839614].
33 Schunemann HJ, Oxman AD, Brozek J, et al. Grading quality of evidence and strength of recommendations for diagnostic tests and strategies. BMJ. 2008;336(7653):1106-10. [pmid: 18483053].
34 Egger M, Davey Smith G, Schneider M, et al. Bias in meta-analysis detected by a simple, graphical test. BMJ. 1997;315(7109):629-34. [pmid: 9310563].
35 Sterne JA, Egger M, Smith GD. Systematic reviews in health care: Investigating and dealing with publication and other biases in meta-analysis. BMJ. 2001;323(7304):101-5. [pmid: 11451790].
36 Cohen LB, Taveira TH, Khatana SA, et al. Pharmacist-led shared medical appointments for multiple cardiovascular risk reduction in patients with type 2 diabetes. Diabetes Educ. 2011;37(6):801-12. [pmid: 22021025].
37 Wagner EH, Grothaus LC, Sandhu N, et al. Chronic care clinics for diabetes in primary care: a system-wide randomized trial. Diabetes Care. 2001;24(4):695-700. [pmid: 11315833].
38 Fowler MJ. Diabetes Treatment, Part 2: Oral Agents for Glycemic Management. Clinical Diabetes. October. 2007;25(4):131-134.
39 Cohen J. Statistical Power Analysis for the Behavioral Sciences (second ed.). Hillsdale, NJ. Lawrence Erlbaum Associates. 1988.
40 Sehestedt T, Hansen TW, Li Y, et al. Are blood pressure and diabetes additive or synergistic risk factors? Outcome in 8494 subjects randomly recruited from 10 populations. Hypertens Res. 2011;34(6):714-21. [pmid: 21307869].
41 Robinson KA, Saldanha IJ, Mckoy NA. Frameworks for Determining Research Gaps During Systematic Reviews, Methods Future Research Needs Report No. 2. (Prepared by the Johns Hopkins University Evidence-based Practice Center under Contract No. HHSA 290-2007-10061-I.) AHRQ Publication No. 11-EHC043-EF. Rockville, MD. Agency for Healthcare Research and Quality. June. 2011. Available at: www.effectivehealthcare.ahrq.gov/reports/final.cfm. Accessed May 22, 2012.