# METHODS

## TOPIC DEVELOPMENT

This review was commissioned by the VA Evidence-based Synthesis Program. The topic was nominated after a topic refinement process that included a preliminary review of published peer-reviewed literature, consultation with internal partners and investigators, and consultation with key stakeholders. We further developed and refined the key questions based on a preliminary review of published peer-reviewed literature in consultation with VA experts.

The final key questions were:

Key Question 1 For adults with chronic medical conditions, do shared medical appointments (SMAs) compared with usual care improve the following:
  - Patient and staff experience?
  - Treatment adherence?
  - Quality measures such as (a) process of care measures utilized by VA, National Quality Forum, or National Committee for Quality Assurance and (b) biophysical markers (laboratory or physiological markers of health status such as HbA1c and blood pressure)?
  - Symptom severity and functional status?
  - Utilization of medical resources or health care costs?
Key Question 2 For adults with chronic medical conditions, do the effects of SMAs vary by patient characteristics such as specific chronic medical conditions and severity of disease?
Key Question 3 Is the intensity of the intervention or the components used by SMAs associated with intervention effects?

## ANALYTIC FRAMEWORK

We followed a standard protocol for all steps of this review; certain methods map to the PRISMA checklist.24 Our approach was guided by the analytic framework shown in Figure 1.

Figure 1 Analytic framework for evaluating shared medical appointments

Abbreviations: CAD=coronary artery disease; CHF=congestive heart failure; COPD=chronic obstructive pulmonary disease; KQ=key question; QOL=quality of life; SMA=shared medical appointment

## SEARCH STRATEGY

We searched MEDLINE^®^ (via PubMed^®^), Embase^®^, CINAHL^®^, PsycINFO and Web of Science for peer-reviewed publications comparing shared medical appointments or group visits with usual care from January 1996 through September 2011. Our search strategy used the National Library of Medicine’s medical subject headings (MeSH) keyword nomenclature and text words for types of visits or clinic appointments, and validated search terms for both randomized controlled trials25 and relevant observational studies adapted from the Cochrane Effective Practice & Organization of Care Group search version 1.9. Our final search terms included terms for group visits together with terms for trials or relevant observational designs. We limited the search to articles published in the English language involving human subjects 18 years of age and older. The full search strategy is provided in Appendix A. An updated search for publications in PubMed was conducted in April 2012. We developed our search strategy in consultation with an experienced search librarian.

We supplemented the electronic searches with a manual search of citations from a set of key primary articles, three review articles and one systematic review.3,4,7,10,11,15,18,19,22,26–28 The reference list for identified pivotal articles was manually hand-searched and cross-referenced against our library in order to retrieve additional manuscripts. All citations were imported into two electronic databases: EndNote^®^ Version X5 (Thomson Reuters; Philadelphia, PA) for referencing and DistillerSR (Evidence Partners; Manotick, ON, Canada) for data abstraction. As a mechanism to assess the risk of publication bias, we searched www.clinicaltrials.gov for completed but unpublished studies in March 2012.

## STUDY SELECTION

Using prespecified inclusion and exclusion criteria, two reviewers assessed titles and abstracts for relevance to the Key Questions (KQs). Full-text articles identified by either reviewer as potentially relevant were retrieved for further review. Each article retrieved was examined by two reviewers against the eligibility criteria (Table 1). Disagreements on inclusion, exclusion, or major reason for exclusion were resolved by discussion or by a third reviewer.

Table 1 Summary of inclusion and exclusion criteria

Study characteristic | Inclusion criteria | Exclusion criteria
Population | Adults (≥18 years) of age with asthma, coronary artery disease, congestive heart failure, chronic obstructive pulmonary disease, diabetes mellitus, hyperlipidemia, hypertension, or combinations of these chronic medical conditions | Populations selected for individuals with substance abuse disorders
Intervention | “Exposure” must meet all the following criteria:; - A series of medical visits (at least two) where at least one health care professional (including a prescribing clinician^a^) cares for a groups of patients; - The medical provider addresses each patient’s unique medical needs individually, with the potential to make changes in medications, but in the context of the group setting | Study excluded if exposure meets any of the following criteria:; - Not a group visit; - No prescribing clinician present at the group visit meeting; - No plan for adjusting medications when indicated
Comparator | Usual care or other quality improvement strategy | None; study must have a control condition
Outcome | - Patient and/or staff experience; - Treatment adherence (attendance, medications, self-management); - Biophysical markers (e.g., HbA1c, blood pressure); - Symptom severity; - Functional status; - Utilization of medical resources | None
Timing | Outcomes reported at least 3 months from randomization and initiation of intervention | Outcomes reported less than 3 months from randomization and initiation of intervention
Setting | - Outpatient settings; specifically, primary care or specialty clinic/practice; - Conducted in North America, Western Europe, Australia/New Zealand | - Conducted in an inpatient or nonmedical community setting (i.e., senior centers, etc.); - Conducted in countries other than those specifically listed as included
Study design^b^ | - Patient or cluster RCTs; - Nonrandomized cluster controlled trials; - Controlled before-and-after studies; - Interrupted time series designs | Cross-sectional studies and other observational study designs not specifically listed as “included” study designs
Publications | - English-language only; - Published from 1996 to present; - Peer-reviewed article | - Non-English language publication; - Published before 1996^c^

a A prescribing clinician may be a medical doctor, doctor of osteopathy, advanced practice registered nurse (APRN), physician assistant, or doctor of pharmacy.

b Study designs recommended by the Cochrane Effective Practice and Organization of Care Group.

c Shared medical appointments were introduced by Beck et al. with their seminal article in 1997.

Abbreviations: HbA1c=glycosylated hemoglobin; KQ=key question; RCT=randomized controlled trial

The criteria to screen articles for inclusion or exclusion at both the title-and-abstract and full-text screening stages are detailed in Table 1. We modified these criteria to include observational studies designs recommended by the Cochrane Effective Practice and Organization of Care Review Group (i.e., controlled before and after, nonrandomized cluster controlled trials, interrupted time-series). Studies excluded at the full-text review stage are listed with the reasons for exclusion in Appendix B.

## DATA ABSTRACTION

Before general use, the abstraction form templates designed specifically for this report were pilot-tested on a sample of included articles and revised to ensure that all relevant data elements (Appendix C) were captured and that there was consistency and reproducibility between abstractors. We designed the data abstraction forms for this project to collect the data required to evaluate the specified eligibility criteria for inclusion in this review, as well as population characteristics and other data needed for determining outcomes (e.g., biophysical markers, resource utilization) and risk of bias. We paid particular attention to describing the details of the intervention, including the clinical team (clinical disciplines represented, team size and continuity), characteristics of the patient group (group size, group continuity, inclusion of family members or peer supports), and group visit processes (individual breakouts, medication changes, visit duration, telephone contacts). In addition, we examined the included articles for subgroup analyses of relevance to our key questions.

One investigator abstracted the data, and the second reviewed the completed abstraction form alongside the original article to check for accuracy and completeness. Disagreements were resolved by consensus or by obtaining a third investigator’s opinion if consensus could not be reached by the first two. We supplemented abstraction of published data by contacting authors for missing information. We contacted 11 of 19 authors; of these, 7 replied with the requested information.

## QUALITY ASSESSMENT

We also abstracted data necessary for assessing quality and applicability, as described in the Agency for Healthcare Research and Quality’s (AHRQ’s) Methods Guide for Effectiveness and Comparative Effectiveness Reviews.29 For RCTs, these key quality criteria consisted of (1) adequacy of randomization and allocation concealment, (2) comparability of groups at baseline, (3) blinding, (4) completeness of followup and differential loss to followup, (5) whether incomplete data were addressed appropriately, (6) validity of outcome measures, and (7) conflicts of interest (Appendix D). Using these quality criteria, we assigned a summary quality score (good, fair, poor) to individual RCTs studies as defined in the Methods Guide.

Threats to internal validity of systematic review conclusions based on observational studies were identified through assessment of the body of observational literature as a whole, with an examination of characteristics of individual studies.29,30 Study-specific issues that were considered include (1) potential selection bias (i.e., degree of similarity between intervention and control patients), (2) performance bias (i.e., differences in care provided to intervention and control patients not related to the study intervention), (3) attribution and detection bias (i.e., whether outcomes were differentially detected between intervention and control groups), and (4) magnitude of reported intervention effects (see the section on “Selecting Observational Studies for Comparing Medical Interventions” in the Methods Guide).29 For each study, one investigator assigned a summary quality rating for “hard outcomes” (e.g., laboratory measures) and a separate rating for “soft” outcomes (e.g., staff experience), which were then reviewed by a second investigator; disagreements were resolved by consensus or by a third investigator if agreement could not be reached.

## DATA SYNTHESIS

We critically analyzed studies to compare their characteristics, methods, and findings. We then determined the feasibility of completing a quantitative synthesis (i.e., meta-analysis) by exploring the volume of relevant literature, the completeness of the results reporting and the conceptual homogeneity of the studies. Because the elderly and individuals with diabetes mellitus are high utilizers of the health care system and are distinct groups of clinical patients with distinct primary endpoints, we examined the groups of studies as they pertained to these target conditions separately.

When a meta-analysis was appropriate, we used random-effects models to synthesize the available evidence quantitatively. For other outcomes we analyzed the results qualitatively. The outcomes amenable to meta-analysis were continuous; we therefore summarized these outcomes by a weighted difference of the means when the same scale (e.g., blood pressure) was used and a standardized mean difference when the scales (e.g., health-related quality of life) differed across studies. We present summary estimates (standardized so that a negative value favors SMA) and 95 percent confidence intervals (95% CIs). Heterogeneity was examined among the studies using graphical displays and test statistics (Cochran’s Q and I^2^); the I^2^ describes the percentage of total variation across studies due to heterogeneity rather than to chance.31 Heterogeneity was categorized as low, moderate, or high based on I^2^ values of 25 percent, 50 percent, and 75 percent respectively. We explored heterogeneity in study effects by using subgroup analyses for categorical variables (e.g., study quality) and meta-regression analyses for continuous or discrete variables (e.g., baseline HbA1c, intervention robustness). We constructed a “robustness score” that could range from 0 to 9, based on 7 intervention elements that were chosen a priori: theoretical framework guiding the intervention, individual breakouts, continuity between patients and clinical team, scheduled visits above the median, and medication changes. The latter two characteristics were scored 0 (absent) or 2 (present); all other items were scored as 0 or 1. We conducted a sensitivity analyses by using only studies whose populations had type 2 diabetes. Our subgroup and meta-regression analyses should be considered hypothesis-generating because they consist of indirect comparisons (across studies that may differ in ways other than the target condition) and thus are subject to confounding.

All basic analyses were conducted using Review Manager (RevMan) 5.1.4. (Copenhagen: The Nordic Cochrane Centre, The Cochrane Collaboration, 2011). Meta-regression analyses were conducted using Comprehensive Meta-Analysis software (Version 2; Biostat, Englewood, NJ).

## RATING THE BODY OF EVIDENCE

In addition to rating the quality of individual studies, we evaluated the overall quality of the evidence for each KQ as described in the Methods Guide.29 In brief, this approach requires assessment of four domains: risk of bias, consistency, directness, and precision. Additional domains considered were strength of association (magnitude of effect) and publication bias. For risk of bias, we considered basic (e.g., RCT) and detailed study design (e.g., adequate randomization). We used results from meta-analyses when evaluating consistency (forest plots, tests for heterogeneity), precision (confidence intervals), strength of association (weighted mean difference), and publication bias (clinicaltrials.gov survey). Optimal information size and consideration of whether the confidence interval crossed the clinical-decision threshold using a treatment model were also used when evaluating precision.32 These domains were considered qualitatively, and a summary rating of high, moderate, low, or insufficient strength of evidence was assigned after discussion by two investigators. This four-level rating scale consists of the following definitions:

- High—Further research is very unlikely to change our confidence on the estimate of effect.
- Moderate—Further research is likely to have an important impact on our confidence in the estimate of effect and may change the estimate.
- Low—Further research is very likely to have an important impact on our confidence in the estimate of effect and is likely to change the estimate.
- Insufficient—Evidence on an outcome is absent or too weak, sparse, or inconsistent to estimate an effect.

When a rating of high, moderate, or low was not possible or was imprudent to make, a grade of insufficient was assigned.33 We also considered the risk of publication bias. Publication bias was addressed through a careful search of www.clinicaltrials.gov for identification of any study completed but unpublished or ongoing. For the single outcome with at least 10 studies, we used graphical (e.g., funnel plots) and test statistics (e.g., Beggs test) to detect publication bias; these methods do not perform well with fewer than 10 studies and thus were not performed for the other outcomes.34,35

## PEER REVIEW

A draft version of the report was reviewed by technical experts and clinical leadership. A transcript of their comments can be found in Appendix E, which elucidates how each comment was considered in the final report.