# INTRODUCTION

Optimal care of chronic illness requires both high-quality care (i.e., excellent clinical outcomes) and ready access to care. However, health care systems struggle with providing access and quality simultaneously—and to achieve both these objectives while simultaneously maintaining staff job satisfaction is a formidable undertaking. Although Veterans Affairs (VA) has made large strides in delivering quality care over the past two decades, quality gaps remain, both gaps in technical quality (e.g., still only 70 to 75% of patients have appropriate blood pressure control1) and gaps in timeliness of services. Group medical visits offer the promise of improving the effectiveness, timeliness, and efficiency of health care. Additionally, because clinicians may prefer to work in collaborative, multidisciplinary settings, group medical visits also have the potential to improve staff satisfaction.2–8

Group medical visits are defined as multiple patients seen together while in the same clinical setting. A subset of group clinics—referred to as shared medical appointments (SMAs)—is defined by groups of patients meeting over time for comprehensive care, usually involving a practitioner with prescribing privileges, for a defining chronic condition or health care state. SMAs often use educational and/or self-management enhancement strategies, paired with medication management, in an effort to achieve improved disease outcomes.

SMAs have been scientifically studied in an array of primary care settings over the last 10 to 15 years.3,5,8–23 However, there has been great variability among these studies. In particular, the settings of these studies have been heterogeneous; different chronic health care states have been assessed; and the impact on clinical, cost, and utilization outcomes has been variable. Most important, there has been significant variation in the SMA intervention itself—in particular, which types of clinical, educational, and self-efficacy approaches are included in the specific SMA under evaluation. This uncertainty regarding the optimal design and impact of SMAs led the VA to commission this evidence synthesis report.

## BACKGROUND

The SMA approach developed as a care redesign strategy over the last 15 years. SMAs are defined as providing group-based, longitudinal medical care for a number of patients who have a common characteristic such as type 2 diabetes.3,5,8,13–20,22,23 This commonality may be a disease (e.g., diabetes), a demographic (e.g., patients over 65 years of age), or some other health care– related element (e.g., high utilization of services). The patient group may stay constant, in an attempt to provide group bonding, or patients may be allowed to attend sessions chosen from a schedule at their own convenience to promote attendance.

In general, SMAs will have more than one health care provider involved; often the care team will include a person trained or skilled in delivering patient education or facilitating patient interaction (nurse, psychologist) and a prescribing provider empowered to make and initiate a comprehensive care plan. Like patients, providers can either be constant with the same patients or vary over time.

SMA sessions usually last from 60 to 120 minutes. Sessions usually have part of their time set aside for social integration, part set aside for interactive education, and part committed to changes in the care plan for the common condition. The education piece is designed to improve self-management skills; educators will often be formally trained in skills such as motivational interviewing to help patients enhance their self-management. Because they involve both self-management improvement along with medication intensification, SMAs have the potential to coordinate these strategies to maximize the effects of each.

SMAs have been touted as a way to improve key elements of health care, particularly access, outcomes, and cost. Improved access is thought to occur because in a drop-in group structure, patients get their chronic illness care when they want it and/or because a group visit is usually shorter than the amount of time it takes to see all patients in the group one-on-one, thereby improving the provider’s throughput and patients’ access to that provider. Improved outcomes are thought to occur because (1) the group provides enhanced self-management education due to more time spent in that education, the use of motivational interviewing by the trained facilitator, or the peer support of members of the group, (2) the group provides a focused environment for care of the common condition or unifying characteristic (e.g., older age) without the distractions of multiple other issues that come up in a brief primary care visit, and/or (3) the group provides access to medication changes performed by a provider with special expertise in the common condition or by a team of providers with synergistic knowledge, thus leading the group to function like a specialty referral. Costs are thought to be lowered because the aforementioned efficiency in throughput leads to lower total costs of care or access to a group keeps patients from using acute-care settings for management of chronic illness, saving the costs associated with unnecessary emergency department visits or hospitalizations.

Early studies of SMAs focused on common demographic characteristics (elderly, high utilization) rather than common illnesses.9,12 However, most recent studies have focused on a common chronic illness as the unifying theme for the SMA, with diabetes the most commonly studied. This may make clinical sense, given that patients with the same chronic illness require self-efficacy for the same self-management skills (e.g., patients with diabetes need to feel empowered to correctly monitor and record blood sugar readings). The disease focus may also be because of the ease of identifying disease-specific clinical outcomes for research studies.

## OBJECTIVE OF THIS REPORT

Our objective in this evidence synthesis was to summarize the results of the diverse studies of SMAs in an effort to understand their impact on staff satisfaction, patient experience, and clinical outcomes along with effects on health care utilization. A second objective was to determine whether the impact of SMA visits varies by clinical condition or specific components of the intervention.