# GLOSSARY

Abstract screening: The stage in a systematic review during which titles and abstracts of articles identified in the literature search are screened for inclusion or exclusion based on established criteria. Articles that pass the abstract screening stage are promoted to the full-text review stage.
Allocation concealment: The method by which randomization assignment is concealed from participants and investigators before and during the enrollment process. Common processes are central allocation (telephone or web-based, pharmacy or off-site statistician controlled randomization sequence generation and sequentially numbered, opaque, sealed envelopes. Allocation concealment concentrates on preventing selection and confounding biases, safeguards the assignment sequence before and until allocation, and can always be successfully implemented
Area under the curve (AUC): The area under the receiver operating characteristic (ROC) curve. The summary receiver operator characteristic (SROC) curve and the AUC have been proposed as a way to assess diagnostic data in the context of a meta-analysis. The accuracy of a diagnostic test depends on how well the test separates the group being tested into those with and without the condition in question.
Case-control study: A retrospective, analytical, observational study often based on secondary data in which the proportion of cases with a potential risk factor are compared to the proportion of controls (individuals without the disease or condition) with the same risk factor. The common association measure for a case-control study is the odds ratio. These studies are commonly used for initial, inexpensive evaluation of risk factors and are particularly useful for rare conditions or for risk factors with long induction periods. Unfortunately, due to the potential for many forms of bias in this study type, case control studies provide relatively weak empirical evidence even when properly executed.
Case report: A description of a single case, typically describing the manifestations, clinical course, and prognosis of that case. Due to the wide range of natural biologic variability in these aspects, a single case report provides little empirical evidence to the clinician. A case report does describe how others diagnosed and treated the condition and what the clinical outcome was.
Case series: A descriptive, observational study of a series of cases, typically describing the manifestations, clinical course, and prognosis of a condition. A case series provides weak empirical evidence because of the lack of comparability unless the findings are dramatically different from expectations. Case series are best used as a source of hypotheses for investigation by stronger study designs, leading some to suggest that the case series should be regarded as clinicians talking to researchers. Unfortunately, the case series is the most common study type in the clinical literature.
ClinicalTrials.gov: A registry and results database of federally and privately supported clinical trials conducted in the United States and around the world. ClinicalTrials.gov provides information about a trial’s purpose, location, participant characteristics, among other details.
Cochrane Database of Systematic Reviews: A bibliographic database of peer-reviewed systematic reviews and protocols prepared by the Cochrane Review Groups in The Cochrane Collaboration.
Cochran’s Q test: A nonparametric statistic to test for differences in intervention effects between studies. Because the test statistic is often underpowered, the threshold for statistically significant differences in intervention effects is often set at p<0.10.
Cohort study: A prospective, analytical, observational study based on data, usually primary, from a followup period of a group in which some have had, have, or will have the exposure of interest, to determine the association between that exposure and an outcome. Cohort studies are susceptible to bias by differential loss to followup, the lack of control over risk assignment, and the potential for zero time bias when the cohort is assembled. Because of their prospective nature, cohort studies are stronger than case-control studies when well executed, but they also are more expensive. Because of their observational nature, cohort studies do not provide empirical evidence that is as strong as that provided by properly executed randomized controlled clinical trials.
Companion article: A publication from a trial that is not the article containing the main results of that trial. It may be a methods paper, a report of subgroup analyses, a report of combined analyses, or other auxiliary topic that adds information to the interpretation of the main publication.
Confidence interval (CI): The range in which a particular result (such as a laboratory test) is likely to occur for everyone in the population of interest a specified percentage of the time known as the confidence level or confidence coefficient. It is an interval calculated from a study’s observations used to estimate the reliability of the estimate of a parameter. The most common confidence level is 95%. For example, a confidence interval with a 95% confidence level is intended to give the assurance that, if the statistical model is correct, then taken over all the data that might have been obtained, the true value of the parameter will be found within the given interval 95% of the time.
Consistency: Extent to which effect size and direction vary within and across studies; inconsistency may be due to heterogeneity across PICOTS.
Cumulative Index to Nursing and Allied Health Literature (CINAHL): A collection of medical databases of nursing and allied health literature.
Data abstraction: The stage of a systematic review that involves a pair of trained researchers extracting reported findings specific to the research questions from the full-text articles that met the established inclusion criteria. These data form the basis of the evidence synthesis.
Directness: Degree to which outcomes that are important to users of the comparative effectiveness review (patients, clinicians, or policymakers) are encompassed by trial data.
Embase: A database containing bibliographic records with citations, abstracts, and indexing derived from biomedical and pharmacological articles in peer-reviewed journals.
Exclusion criteria: The criteria, or standards, set out before a study or review. Exclusion criteria are used to determine whether a person should participate in a research study or whether an individual study should be excluded in a systematic review. Exclusion criteria may include age, previous treatments, and other medical conditions.
External validity: The extent to which clinical research studies apply to broader populations. A research study has external validity if its results can be generalized to the larger population.
Forest plot: A visual display of information from individual studies in a meta-analysis. A forest plot shows the amount of variation between the results of the studies as well as an estimate of the overall result of all the studies together. A horizontal line represents the 95% confidence interval (CI) of the “effect” observed in the studies.
Full-text review: The stage of a systematic review in which a pair of trained researches evaluates the full-text of study articles for potential inclusion in the review.
GRADE: Grading of Recommendations Assessment, Development and Evaluation (GRADE), a systematic approach to evaluating the overall body of research evidence and rating the quality of medical evidence and the strength of clinical recommendations.
Health-related quality of life (HRQOL): Aspects of overall quality of life that can be clearly shown to affect health—either physical or mental health.
I ^2^: A statistic that describes the percentage (range from 0–100%) of total variation across studies due to heterogeneity between study characteristics rather than due to chance. Heterogeneity is categorized as low, moderate or high based on I^2^ values of 25, 50 or 75%, respectively. It is considered an indication of consistency or inconsistency across studies in a meta-analysis.
Inclusion criteria: The criteria, or standards, set out before the systematic review. Inclusion criteria are used to determine whether an individual study can be included in a systematic review. Inclusion criteria may include population, study design, gender, age, type of disease being treated, previous treatments, and other medical conditions.
Intent-to-treat analysis: A method of analyzing results of a randomized controlled trial that includes in the analysis all cases that should have received a treatment regimen but for some reason did not. All cases allocated to each arm of the trial are analyzed together as representing that treatment arm, regardless of whether they received or completed the prescribed regimen.
Interquartile range (IQR): A measure of the spread of or dispersion within a data set. The IQR is the width of an interval that contains the middle 50 percent of the sample, so it is smaller than the range and its value is less affected by outliers.
Meta-analysis: A way of combining data from many different research studies. A meta-analysis is a statistical process that combines the findings from individual studies.
Meta-regression analyses: An extension of meta-analysis to subgroups that allows the effect of continuous, as well as categorical, characteristics to be investigated if sufficient studies examining the same characteristics may be compared. In principle, it allows the effect of multiple factors to be investigated simultaneously. In meta-regression, the outcome variable is the effect estimate (e.g., a mean difference, etc.). The explanatory variables are characteristics of studies that might influence the size of the intervention effect.
Mixed effects: Statistical models that include both fixed (nonrandom) and random effects.
National Committee for Quality Assurance (NCQA): A nonprofit organization dedicated to improving health care quality.
National Quality Forum (NQF): A nonprofit organization that promotes change through development and implementation of a national strategy for health care quality measurement and reporting.
Negative predictive value (NPV): The likelihood that people with a negative test result would not have a condition. The higher the value of the negative predictive value (for example, 99 percent would usually be considered a high value), the more useful the test is for predicting that people do not have the condition.
Nonrandomized study: Any quantitative study estimating the effectiveness of an intervention (harm or benefit) that does not use randomization to allocate units to comparison groups (including studies where “allocation” occurs in the course of usual treatment decisions or peoples’ choices; i.e., studies usually called “observational”). There are many possible types of nonrandomized intervention studies, including cohort studies, case-control studies, controlled before-and-after studies, interrupted-time-series studies, and controlled trials that do not use appropriate randomization strategies (sometimes called quasi-randomized studies).
Observational study: A study in which the investigators do not seek to intervene but simply observe the course of events. Changes or differences in one characteristic (e.g., whether or not people received the intervention of interest) are studied in relation to changes or differences in other characteristics (e.g., whether or not they died), without action by the investigator. Observational studies provide weaker empirical evidence than do experimental studies because of the potential for large confounding biases to be present when there is an unknown association between a factor and an outcome.
Odds ratio: A ratio of the odds of having the outcome of interest in a group with a particular exposure, symptom, or characteristic of interest, to the odds of outcome in a group that does not have the exposure/symptom/characteristic. An odds ratio of 1 indicates that the outcome is equally likely to occur in both groups. An odds ratio of 4 indicates that the outcome is 4 times more likely to be present in the group that has the symptom or characteristic of interest, compared with the group that does not have this symptom. When outcomes are infrequent, the odds ratio is a good approximation of the risk ratio.
Outlier: An observation in a data set that is far removed in value from the others in the data set. It is an unusually large or an unusually small value compared to the others.
Patient-centered adult learning: An approach used in the professional–patient interaction. Common elements are empathic communication, acknowledgement, realistic expectations, goal negotiation, guided problem-solving, individualized strategies, and ongoing support.
PICOTS: Population, intervention, comparator, outcome, timing, setting.
Positive predictive value (PPV): Indicates the likelihood that a person with a positive test result would actually have the condition for which the test is used. The higher the value of the positive predictive value (for example, 90 percent would be considered a high value), the more useful the test is for predicting that the person has the condition.
Precision: The degree of certainty for estimate of effect with respect to a specific outcome.
Preferred Reporting Items of Systematic Reviews and Meta-Analyses (PRISMA): An evidence-based minimum set of items for reporting in systematic reviews and meta-analyses.
Probability: The likelihood (or chance) that an event will occur. In a clinical research study, it is the number of times a condition or event occurs in a study group divided by the number of people being studied.
Process of care or performance measure: Quality measures used to gauge how well an entity provides care to its patients. Measures are based on scientific evidence and usually reflected in guidelines, standards of care or practice parameters.
Prospective observational study: A clinical research study in which people who presently have a certain condition or receive a particular treatment are followed over time and compared with another group of people who are not affected by the condition.
PsycINFO: An abstracting and indexing database of peer-reviewed literature in the behavioral sciences and mental health.
Publication bias: The tendency of researchers to publish experimental findings that have a positive result, while not publishing the findings when the results are negative or inconclusive. The effect of publication bias is that published studies may be misleading. When information that differs from that of the published study is not known, people are able to draw conclusions using only information from the published studies.
PubMed: A database of citations for biomedical literature from MEDLINE, life science journals, and online books in the fields of medicine, nursing, dentistry, veterinary medicine, the health care system, and preclinical sciences.
QUADAS: Quality Assessment of the Diagnostic Accuracy Studies, a tool that uses a standard methodology to judge the quality of individual studies in a systematic review.
Quasi-experimental study: A quasi-experimental study manipulates a variable between two or more groups, but participants are not randomly assigned to groups. Quasi-experimental study designs, such as nonrandomized pre-post studies, are frequently used when it is not logistically feasible or ethical to conduct a randomized controlled trial.
Quasi-random allocation: Methods of allocating people to a trial that are not random but were intended to produce similar groups when used to allocate participants. Quasi-random methods include allocation by the person’s date of birth, by the day of the week or month of the year, by a person’s medical record number, or just allocating every alternate person. In practice, these methods of allocation are relatively easy to manipulate, introducing selection bias.
Randomized controlled trial: A prospective, analytical, experimental study using primary data generated in the clinical environment. Individuals similar at the beginning of the trial are randomly allocated to two or more treatment groups and the outcomes the groups are compared after sufficient followup time. Properly executed, the RCT is the strongest evidence of the clinical efficacy of preventive and therapeutic procedures in the clinical setting.
Relative risk (RR): A comparison of the risk of a particular event for different groups of people. Relative risk is usually used to estimate exposure to something that could affect health. In a clinical research study, the experimental group is exposed to a particular drug or treatment. The control group is not. The number of events in each group is compared to determine relative risk.
Reporting bias: A bias caused by only a subset of all the relevant data being available. The publication of research can depend on the nature and direction of the study results. Studies in which an intervention is not found to be effective are sometimes not published. Because of this, systematic reviews that fail to include unpublished studies may overestimate the true effect of an intervention. In addition, a published report might present a biased set of results (e.g., only outcomes or subgroups where a statistically significant difference was found).
Risk: A way of expressing the chance that something will happen. It is a measure of the association between exposure to something and what happens (the outcome). Risk is the same as probability, but it usually is used to describe the probability of an adverse event. It is the rate of events (such as breast cancer) in the total population of people who could have the event (such as women of a certain age).
Robustness score: A score developed to indicate the number of intervention components hypothesized to be associated with greater treatment effects.
Sensitivity: The ability of a test to identify correctly people with a condition. A test with high sensitivity will nearly always be positive for people who have the condition (the test has a low rate of false-negative results). Sensitivity is also known as the true-positive rate.
Shared medical appointment (SMA): A group visit where multiple patients are seen together for followup or routine care.
Spearman’s correlation: A rank correlation coefficient that is usually calculated on occasions when it is not convenient, economical, or even possible to give actual values to variables but only to assign a rank order to instances of each variable. It may also be a better indicator that a relationship exists between two variables when the relationship is nonlinear.
Specificity: The ability of a test to identify correctly people without a condition. A test with high specificity will rarely be wrong about who does not have the condition (the test has a low rate of false-positive results). Specificity is also known as the true-negative rate.
Stages-of-change model: A common health behavioral model consisting of these components: precontemplation, contemplation, preparation, action, and maintenance.
Standard error: The standard deviation of the sampling distribution of a statistic. Measurements taken from a sample of the population will vary from sample to sample. The standard error is a measure of the variation in the sample statistic over all possible samples of the same size. The standard error decreases as the sample size increases.
Standardized mean difference (SMD): The difference between two estimated means divided by an estimate of the standard deviation. It is used to combine results from studies using different ways of measuring the same concept, e.g. mental health. By expressing the effects as a standardized value, the results can be combined since they have no units.
Statistical significance: A mathematical technique to measure whether the results of a study are likely to be true. Statistical significance is calculated as the probability that an effect observed in a research study is occurring because of chance. Statistical significance is usually expressed as a P-value. The smaller the P-value, the less likely it is that the results are due to chance (and more likely that the results are true). Researchers generally believe the results are probably true if the statistical significance is a P-value less than 0.05 (p<.05).
Strength of evidence (SOE): A measure of how confident reviewers are about decisions that may be made based on a body of evidence. SOE is evaluated using one of four grades: (1) High confidence that the evidence reflects the true effect; further research is very unlikely to change reviewer confidence in the estimate of effect; (2) moderate confidence that the evidence reflects the true effect; further research may change the confidence in the estimate of effect and may change the estimate; (3) low confidence that the evidence reflects the true effect; further research is likely to change the confidence in the estimate of effect and is likely to change the estimate; and (4) insufficient; the evidence either is unavailable or does not permit a conclusion.
Summary receiver operating characteristic (SROC): A data analysis approach that combines independent studies of diagnostic tests. The SROC curve and the area under the curve (AUC) have been proposed as a way to assess diagnostic data in the context of a meta-analysis.
Systematic review: A summary of the clinical literature. A systematic review is a critical assessment and evaluation of all research studies that address a particular clinical issue. The researchers use an organized method of locating, assembling, and evaluating a body of literature on a particular topic using a set of specific criteria. A systematic review typically includes a description of the findings of the collection of research studies. The systematic review may also include a quantitative pooling of data, called a meta-analysis.
Time-series study: A quasi-experimental research design in which periodic measurements are made on a defined group of individuals both before and after implementation of an intervention. Time series studies are often conducted for the purpose of determining the intervention or treatment effect.