# SMA INTERVENTION COMPONENTS

Table H-1 SMA interventions: team and process components

| Clinical Team | | Group | | Group Visit Processes
Study | Clinical disciplines | Team continuity Team size | Closed? Group size | Family or peers allowed? | Individual breakouts? | Medication changes? | Visit duration (minutes) | Telephone contacts?
Beck, 1997 | MD, RN, and psychologists (as guest lecturers) | Specific group but rotated ≥2 | Yes 8^a^ | Yes | Yes | Yes | 120 | Yes
Bray, 2005 | MD, RN, and/or others (type NR) | Yes 2 | Yes 3–12 | NR | Yes | Yes | 120 | NR
Clancy, 2003 | MD, nurse practitioner, and guest presenters | Yes 2–3 | Yes 19–20 | NR | Yes | Yes | 120 | No
Clancy, 2007 | MD and RN | Yes 2 | Yes 6–7 | No | Yes | Yes | 120 | No
Cohen, 2011 | Pharmacist, RN, physical therapist and dietitian | Yes 4 | Yes 4–6 | Yes | NR | Yes | 60 | No
Culhane-Pera, 2005 | Exercise specialist, MD, RN, and social worker | Yes 7 | Yes 10–16 | Yes | NR | Yes | 210 | NR
Edelman, 2010 | Health educator, MD, pharmacist, or RN | Yes 3 | Yes 7–8 | No | Yes | Yes | 90–120 | Yes
Gutierrez, 2011 | MD, pharmacist, RN, and social worker | NR 7 | No NR | NR | NR | NR | NR | NR
Kirsh, 2007 | MD, nurse practitioner, pharmacist, psychologist, and/or RN | Yes 5 | No ≤8 | NR | Yes | Yes | Varied >60 | NR
Levine, 2010 | MD and nurse practitioner | Yes 3 | Yes 25 | NR | Yes | Yes | 90 | NR/unclear
Naik, 2011 | MD | Yes ≥2 | Yes 5–7 | No | Yes | Yes | 120 | No
Sadur, 1999 | Behaviorist, dietician, pharmacist, and RN | Yes 4 | Yes 10–18 | No | Yes | Yes | 120 | Yes
Scott, 2004 | MD, pharmacist, RN, physical therapist, and occupational therapist | Yes ≥2 | No 7.7^a^ | Yes | Yes | Yes | 120 | No
Taveira, 2010 | Dietician, pharmacist, physical therapist, and RN | Yes Unclear | Yes 4–8 | Yes | NR | Yes | 120 | No
Taveira, 2011 | Pharmacist and RN | Yes Unclear | No 4–6 | Yes | No | Yes | 120 | No
Trento, 2001 | Health educator and MD | Partial^c^ 2–3 | Yes 9–10 | Yes | Yes | Yes | 50–80 | No
Trento, 2005 | MD and psychopedagogist | Partial^c^ 2 | Yes 6–7 | Yes | Yes | Yes | 40–80 | No
Trento, 2010 | Health educator and MD | Partial^c^ 2 | Yes 9–10 | Yes | Yes | Yes | 60 | No
Wagner, 2001 | MD, pharmacist, and RN | Yes 3 | Yes 6–10 | NR | Yes | NR | 60 | No

a Group size: In these cases, a mean value rather than a range is reported in the article.

b Medication changes: This article did not clearly report whether medication changes were made as part of the group process; however, it is implied in that an MD and a pharmacist were usually present, and the intervention group both lowered their HbA1c and started taking more aspirin than the control group.

c Trento studies: The investigators relied on a pool of health providers for group intervention, which may provide patients with the possibility to see the same provider more than once—hence, team continuity is partially present.

Table H-2 SMA interventions: educational and behavioral components

Study | Leader(s) of Educational Session | Behavioral Approach | Patients Input on Topics? | Topics | Behavioral Strategies | Print Material?
Beck, 1997 | MD, pharmacist, RN, or other team member | NR | No | Medication management, nutrition, physical activity | NR | Yes, generic
Bray, 2005 | RN or other team member | NR | NR | Disease-specific education, medication management, nutrition | Goal-setting, personalized plan | NR
Clancy, 2003 | MD, RN, or guest lecturers | NR | Yes | Disease-specific education, medication management, nutrition, physical activity | NR | NR
Clancy, 2007 | MD | NR | Yes | Disease-specific education, medication management, nutrition, physical activity | NR | NR
Cohen, 2011 | Pharmacist | NR | No | Disease specific education, medication management, nutrition, physical activity | Goal-setting, homework assignments, personalized care plan, self-monitoring | Yes
Culhane-Pera, 2005 | RN | NR | No | Disease-specific education, medication management, nutrition, physical activity | Goal-setting, problem-solving skills | NR
Edelman, 2005 | Health educator or RN | NR | Yes | Disease-specific education, medication management, nutrition, physical activity | Personalized care plan | Yes, generic
Gutierrez, 2011 | Social worker | NR | NR | NR | NR | NR
Kirsh, 2007 | Health psychologist | NR | NR | Disease-specific education nutrition, smoking cessation | Personalized plan | Yes, generic
Levine, 2010 | MD or RN | NR | Yes | Medication management, nutrition, physical activity | NR | Yes, generic
Naik, 2011 | Study clinician | NR | No | Disease-specific education, medication management | Goal-setting, personalized plan, problem-solving skills, self-monitoring | Yes, tailored
Sadur, 1999 | Dietician, health behavior specialist, pharmacist, podiatrist, or RN | NR | Yes | Disease-specific education, physical activity | Personalized plan | NR
Scott, 2004 | Dietician, MD, pharmacist, physical therapist, or RN | NR | Yes | Disease-specific education, medication management, nutrition, physical activity | NR | Yes tailored
Taveira, 2010 | Dietician, pharmacist, physical therapist, or RN | Stages of change | No | Disease-specific education, medication management, nutrition, physical activity, smoking cessation | NR | Yes, tailored
Taveira, 2011 | Nutritionist, pharmacist, or RN | Stages of change | No | Disease-specific education, medication management, nutrition, physical activity, smoking cessation | NR | Yes, tailored
Trento, 2001 | MD or health educator | Patient-centered adult learning | No | Disease-specific education, medication management, nutrition, physical activity, smoking cessation | Homework assignment, problem-solving skills, self-monitoring | Yes, tailored
Trento, 2005 | MD or health educator | Patient-centered adult learning | Yes | Disease-specific education, medication management, nutrition, physical activity, self-care | Homework assignment, problem-solving skills, self-monitoring | Yes, tailored
Trento, 2010 | MD or health educator | Patient-centered adult learning | No | Disease-specific education, medication management, nutrition, physical activity, smoking cessation | Homework assignment, problem-solving skills, self-monitoring | Yes, tailored
Wagner, 2001 | RN or other health professional | NR | No | Disease-specific education | Self-monitoring | Yes, generic