# SMA STUDY CHARACTERISTICS

Table G-1 SMA study characteristics

Study | Location Setting Organization Total N | Age in Years (SD) Sex (%) Race/ethnicity (%) | Target Condition Mean Baseline HBA1c % (SD) (for Diabetes Studies) | SMA Planned Visits Study Duration | Comparator | Quality
Beck, 1997 | US Primary care HMO 321 | 73.5 (NR) Male (34%) NR | Chronically ill older adults Not applicable | 12 >12 months | Usual care | Poor
Bray, 2005 | US Primary care University-affiliated clinic 160 | 59.4 (14.3) Male (44%) NR | Diabetes; hypertension HBA1c: 8.2 (2.4) | 4 12 months | Usual care | Fair
Clancy, 2003 | US Primary care University-affiliated clinic 120 | 54.0 (NR) Male (22%) Black (77.5%) | Type 2 diabetes HBA1c: 10.4 (NR) | 6 6 months | Usual care | Good
Clancy, 2007 | US Primary care University-affiliated clinic 186 | 56.0 (NR) Male (28%) Black (83.3%) | Type 2 diabetes HBA1c: 9.1 (2.0) | 12 12 months | Usual care | Fair
Cohen, 2011 | US Primary care VA Health system 99 | 69.8 (10.7) Male (100%) NR | Type 2 diabetes HbA1c: 7.8 (1.0) | 4 once weekly + 5 monthly booster session 6 months | Usual care | Fair
Culhane-Pera, 2005 | US Federally qualified health center Government 61 | 56.8 (NR) Male (36%) NR | Type 2 diabetes HBA1c: 9.4 (NR) | 7 visits 28 months | Usual care | Poor
Edelman, 2010 | US Primary care VA Health system 239 | 62.0 (9.7) Male (96%) Black (59.0%) | Diabetes; hypertension HBA1c: 9.2 (1.4) | 7 visits 12 months | Usual care | Good
Gutierrez, 2011 | US Primary care University-affiliated clinic 103 | NR (NR) Male (NR) Hispanic (100%) | Type 2 diabetes HBA1c: NR (NR) | 36 visits offered 17 months | Usual care | Poor
Kirsh, 2007 | US Primary care VA Health system 79 | 61.0 (9.9) Male (NR) NR | Type 2 diabetes HBA1c: 10.1 (NR) | NA (drop-in) 4 months ) | Usual care | Fair
Levine, 2010 | US Primary care HMO 1236 | 78.2 (7.2) Male (35%) NR | High usage of clinic services Not applicable | 12 visits 12 months | Usual care | Fair
Naik, 2011 | US Primary care VA Health system 87 | 63.6 (7.9) Male (NR) Black (31.0%) | Type 2 diabetes HBA1c: 8.8 (1.3) | 4 visits 3 months intervention; 12 months followup | Enhanced usual care (2 required diabetes group education sessions) | Good
Sadur, 1999 | US Primary care HMO 185 | 56.0 (9.1) Male (57%) White (74.6%) | Types 1 and 2 diabetes HBA1c: 9.7 (1.7) | 6 visits 6 months | Usual care | Good
Scott, 2004 | US Primary care HMO 294 | 74.1 (7.5) Male (41%) NR | Older; high usage of clinic services Not applicable | 24 visits 24 months | Usual care | Fair
Taveira, 2010 | US Primary care VA Health system 118 | 64.4 (10.3) Male (95%) White (91.0%) | Type 2 diabetes HBA1c: 8.0 (1.3) | 4 visits 1 month (outcomes reported at 4 months) | Usual care | Fair
Taveira, 2011 | US Primary care VA Health system 88 | 60.8 (9.6) Male (98% White (99%) | Types 1 and 2 diabetes HBA1c: 8.4 (1.8) | 9 visits 6 months | Usual care | Good
Trento, 2001 | Italy Diabetes clinic University-affiliated clinic 112 | 61.5 (NR) Male (54%) NR | Type 2 diabetes HBA1c: 7.4 (1.4) | 7–8 visits 24 months | Usual care plus individual education sessions | Fair
Trento, 2005 | Italy Diabetes clinic University-affiliated clinic 62 | Median 27–31 (NR) Male (60%) NR | Type 1 diabetes HBA1c: 8.7 (1.2) | 15 visits 36 months | Usual care plus individual education sessions | Fair
Trento, 2010 | Italy Diabetes clinic University-affiliated clinic 815 | 69.3 (8.4) Male (51%) NR | Type 2 diabetes HBA1c: 7.8 (1.6) | 14 visits 48 months | Usual care; followup scheduled every 3 months | Good
Wagner, 2001 | US Primary care HMO 707 | 60.7(NR) Male (53%) White (72.8%) | Types 1 and 2 diabetes HBA1c: 7.5 (NR) | 8 visits 24 months | Usual care | Fair