# ONGOING CLINICAL TRIALS

Table F-1 Ongoing clinical trials

Official study title | Organization | Intervention | Comparator | Sponsor and ClinicalTrials.gov ID | Funding Start/Stop | Status
Interprofessional Training for Improving Diabetes Care | Government | Shared medical appointments to promote establishing collaborative teams (ReSPECT) | Traditional diabetes education and teleconsultation | Department of Veterans Affairs NCT00854594 | Sep 2010–Sep 2012 | Recruiting
Initiating Diabetic Group Visits in Newly Diagnosed Diabetics in an Urban Academic Medical Practice | University-affiliated clinic | Group Visit | Standard individual medical appointment | Oregon Health and Science University NCT01497301 | Feb 2012–Feb 2013 | Not yet open for participation
Heart Failure Group Clinic Appointments: Rehospitalization | University-affiliated clinic | Heart Failure Group Clinic Appointments | Standard heart failure education | Carol Smith, RN, PhD, FAAN (NHLBI) NCT00439842 | Mar 2007–Sep 2012 | Ongoing, but not recruiting
Group Intervention for DM Guideline Implementation | Government | Pharmacist-led group medical visits for patients with type 2 diabetes mellitus | Usual care | Department of Veterans Affairs NCT00554671 | May 2008–June 2012 | Ongoing, but not recruiting participants

Abbreviations: DM=diabetes mellitus; NHLBI=National Heart, Lung, and Blood Institute