# PEER REVIEW COMMENTS

Reviewer | Comment | Response
Question 1: Are the objectives, scope, and methods for this review clearly described?
1 | Yes. The authors present the objectives and scope in a very succinct fashion. The methods are described in great detail. The key questions for review are very relevant in my opinion. Key question 1(KY 1) was well defined and the authors found 18 studies to evaluate. However KY2 and 3 are quite broad and not as clearly defined as KY 1. (Page 1, line 43, Page 2, Line 2). As there were not enough studies to address these questions, I can only speculate that if the questions were more focused, that the authors would have had better luck. They are to be commended for a thorough and detailed lit review, anyway to answer the call. | Thank you. The key questions were developed in collaboration with our stakeholders.
2 | Yes. The terms “objectives” and “scope” were not used exactly; however the intent of this section was clearly described. The methods were superbly articulated. | Thank you.
3 | Yes. Very clear. | Acknowledged
4 | Yes. No comment. | Acknowledged
5 | Yes. No comment. | Acknowledged
6 | Yes. But comments under question 4. | Acknowledged
7 | Yes. No comment. | Acknowledged
Question 2: Is there any indication of bias in our synthesis of the evidence?
1 | No. No comment. | Acknowledged
2 | No. Risk of bias was evaluated when rating the body of evidence. Threats to internal validity of the systematic review conclusions were accounted for in potential selection bias, performance bias, and attribution and detection bias. Bias was accounted for by using criteria in the quality assessment tool in Appendix D for the review of the literature. | Thank you.
3 | No. No comment. | Acknowledged
4 | No. No comment. | Acknowledged
5 | No. No comment. | Thank you.
6 | No. But comments under question 4. | Acknowledged
7 | No. No comment. | Acknowledged
Question 3: Are there any [underlined: published] or [underlined: unpublished] studies that we may have overlooked?
1 | No. Not that I am aware of. | Acknowledged
2 | No. Not that I am aware of. | Acknowledged
3 | No. No comment. | Acknowledged
4 | No. I am not a SME on this topic so I may not be aware of some overlooked studies. | Acknowledged
5 | Yes. I have unpublished retrospective pre-test/post-test study data awaiting consideration for publication from Diabetes Care Journal. N=1170 with ~ 1% A1c level drop. | Thank you for informing us about your data. We were unable to obtain a copy of this manuscript prior to finalizing our report.
6 | No. I am not aware of any, but I would be surprised if I knew of them from routine practice while the authors used a rigorous process. They do not include the many group interventions directed at weight control. I am not sure why these escaped their search criteria. I think they are not viewed as medical appointments by indexers, even though most would think the programs defined by the AHEAD study or even many MOVE! programs are medical encounters | Our focus on specific chronic conditions—asthma, coronary artery disease, congestive heart failure, chronic obstructive pulmonary disease, diabetes mellitus, hyperlipidemia, hypertension—was developed in collaboration with stakeholders. Obesity was considered but not included since medication management is not as prominent a component compared to the included conditions.
7 | Yes. Published - Cohen, L. B., Taveira, T. H., Khatana, S. A., Dooley, A. G., Pirraglia, P. A., & Wu, W. C. (2011). Pharmacist-led shared medical appointments for multiple cardiovascular risk reduction in patients with type 2 diabetes. [Randomized Controlled Trial Research Support, Non-U.S. Gov’t]. Diabetes Educ, 37(6), 801–812. doi: 10.1177/0145721711423980 | Thank you for making us aware of this study. It was published after our literature search but is now included in the review.
| Unpublished - Pharmacist-led Group Medical Visits to Help With Diabetes Management (MEDIC-1 year), NCT00554671 | Thank you for making us aware of this study. It has been added to the appendix of ongoing clinical trials.
Question 4: Please write additional suggestions or comments below. If applicable, please indicate the page and line numbers from the draft report
1 | Few suggestions include:
1 | 1. (Page 3, Line 13) of executive summary: Mentioning the duration of the studies for the reader to get a snapshot would beneficial, as meaningful change in chronic disease takes time. See below. | 1. We added the range of followup to this section.
1 | 2. (Page3, Line 37) of the executive summary: SMAs were associated with lower A1c than usual care (mean difference=0.58; 95% CI, −1.05 to −0.11) Again mentioning the time frame would be useful, especially as this was one of the main outcomes of their work. It is described on (page 22, line 18), assessed at 6 months to 4 years. | 2. Thank you. This addition was made.
1 | 3. Page 24: Figure 4. Forest plots for meta-analysis on cholesterol. The headings for mean and SD says (mm Hg). Should say (mg/dl). I believe this is an error. | 3. Thank you. This correction was made.
1 | 4. Page 24: Figure 5. Headings for mean SBP, should say (mmHg) | 4. Thank you. This correction was made.
1 | I would like to commend the authors very highly for undertaking this extensive review. There is certainly great need to recognize, investigate and assess newer models of care for chronic illness in the 21^st^ century. They present the current state of chronic illness care clearly, (page 8, line 22–26) which forms a nice background to the topic The methodology used is described in great detail and clear. Their conclusion after an extensive rigorous analysis of the literature highlights how complicated and inter-linked management of chronic disease really is. Their conclusion is not overstated. | Thank you.
1 | In the past decade, several breakthrough collaboratives introducing quality improvement methodology, rather than RCT’s have been implemented in the US, mainly focusing on system improvements to address some of the key questions cited by the authors and addressing the six aims outlined by the Institute of medicine. This review did not analyze them. Only 18 studies qualified for analysis by the methods for SMA’s being a newer model of care. | We followed the Cochrane Effective Practice and Organization of Care guidance, and included comparative patient or cluster RCTs, nonrandomized cluster controlled trials, controlled before-and-after studies, and interrupted time series designs. Any published breakthrough collaborative studies meeting these design specifications would have been included.
1 | As several components are inter-linked that leads to improvement in this model, it was hard to show significance with the rigor used in RCT’s, the gold standard, as seen in this review. So in terms of future research, I am not convinced that large scale RCT’s to address for e.g. diabetes outcomes will be feasible and answer the question described in (Table ES-2: evidence gaps and future research). One thought is to look at different models of care scientifically, to identify best practices and health systems with improved outcomes along with the economic cost for chronic illness management. | As stated above, we included comparative nonrandomized designs. We have modified the future research table to include these study design options.
1 | In conclusion, this paper has many strengths. (As cited by the authors). It is well described, clear and thoughtful with an exhaustive review and analysis of the literature. Going forward, it is an important topic for discussion in primary care and I greatly appreciate the opportunity to review this work. | Thank you.
2 | On page 8 of the document (numbered as page 4), I noted in this paragraph, there needs to be a change in this word (see below in red). Put page/paragraph here | We have made this change.
2 | All three studies showed fewer hospital admissions in …… | The typo “shower” was changed to “showed.”
2 | In addition, on page 13 under the table where there are words describing what is meant by “provider”, would you consider changing advance nurse practitioner to this Advanced Practice Registered Nurse (APRN) as this is the more correct term to describe the nurse provider. Thank you. | We made the suggested change.
3 | No comment from reviewer 5. | Acknowledged
4 | The scope of this data synthesis severely limited by limited number of high quality studies. It would seem that sufficient studies of sufficient design were not available to address KQ2 and KQ3. KQ1 of interest but only addresses initial questions of SMA effectiveness, and then only in diabetes. Some Tables not self-explanatory, such as Table ES-1 which refers to consistency, directness and precision but the definitions and measurement not clearly described. | We reviewed all Tables and edited or footnoted so that tables will “stand on their own.”
4 | More analysis of issues raised in page 9 paragraph 2 would be helpful. Most of the SMA intervention studies suggest deployment of significant employee resources, sometimes on a limited number of patients in the group visit. These additional resources may have been largely responsible for the small improvement in intermediate outcomes seen in diabetes SMA. Left unresolved is whether it is worthwhile for facilities to invest these resources without clear return on investment. And for which patients? | We agree that this is a critical issue and attempted to determine factors associated with effect. Given the limits on intervention reporting and relatively small number of studies, our analysis did not identify the critical factors. For resource use, we were limited to the small amount of data reported.
5 | p.9 2^nd^ paragraph additional reasons for improved outcomes of SMA to consider-interprofessional synergism and motivational interviewing that goes on in the discussion section of SMA’s. | Thank you. These are good points that have been added to the introduction.
5 | p.33 Table 6 Implementation issues-not clear that MD was most prevalent prescribing clinician if pharmacist & nurse practitioners listed with MD or without an MD were mentioned 11 studies and MD prescribers only as 8 times -may want to say have a prescribing clinician present. | We have attempted to clarify by describing the clinical leads and team composition in more detail (see KQ 3 results) and modifying the implementation table to reflect that a prescribing clinical is needed, rather than an MD.
6 | RE: EXECUTIVE SUMMARY
6 | I note that the executive summary is readable in length and well formatted. The writing is clear and crisp, which will be helpful to the eventual consumer. | Thank you.
6 | However, I am disappointed in several aspects of the presentation and data selected for presentations:
6 | The Executive Summary emphasizes quantitative over qualitative commentary. There is very little discussion of the specific aspects of the interventions that are studied; if the reader is not familiar with what goes on in an SMA, then they won’t know after reading this, either. Similarly, one has very little information about what the usual care control treatments are, or how one qualifies to get into the study. There is no exploration of the mechanism of action. | Thank you. We added a description of the common intervention components to the executive summary and the KQ 3 results. We have also added a section on the comparison condition in the initial description of the studies.
6 | Although I recognize that the summary must be brief, it is hard to imagine that all the tables pointing out that it is not possible to draw definitive conclusions based on a couple of studies of non-diabetic high users, or draw conclusions about economic effects when most studies did not report them. | Results are briefly summarized in text. The table also summarizes results but adds the strength of evidence (SOE). Unfortunately, the SOE was insufficient for many outcomes
6 | This is especially disappointing since the readers are not naïve – they are likely to be aware of the literature suggesting a benefit from SMA based on prominent studies, several in VA, that have had this finding. What the reader needs is guidance regarding what one should or should not do if one is attempting to be evidence based. I think that requires description of commonalities in the study designs, even if you can’t comment on whether one aspect or another was demonstrably better. | Unfortunately, the literature does not yet establish the characteristics of SMA associated with benefit. However, in the KQ 3 results, we describe the common features and echo these findings in the discussion.
6 | Since the introduction suggests a couple mechanisms of action, perhaps one could say whether the results say anything about these. In the case of improved access, for example, I guess the answer is that this is NOT the mechanism, since the control people would have also benefited from the provider having more clinic slots. Similarly, if the mechanism were expertise, I would like to see commentary on the expertise of the providers who participated in the SMA – my sense from the articles I have reviewed is that they are not content area experts. | Thank you. This is a good point, but few studies reported intermediate outcomes (e.g., self-management behaviors) or provider training. We report the available results and have added to the discussion the point that few studies report on the potential mechanisms of action.
6 | RE: METHODS | The research team included physicians (one who is expert in shared medical appointments) and psychologists. Our goal was to summarize the evidence so that policy makers could incorporate the best available evidence into decision making.
6 | I think that these are well described. But I wish that there was more of a sense that clinical experts were doing the synthesis and they were thinking about how they made sense. The AHRQ methodology does not seem to exclude this. Moreover, I acknowledge it seems like it is not very rigorous and might be open to bias on the part of the reviewers. So I think that this is why you have people like me review the opinion and offer a counterpoint. And I am confident that the Durham VA and Duke has a lot of people who could offer opinions and give the consumer confidence that the recommendations are in the end based on opinion, but very well informed and vetted opinion.
6 | Thus, I would like to see an attempt to present the rationale for why they think they won’t change their mind (i.e., strength of evidence “High”) or that they are not yet convinced. I would not want this to be devoid of quantitative thinking, rather, I would like an exposition of why they think what they think – this can be that it just does not make sense or that it is very consistent with lots of less strong studies or that the quantitative analysis is particularly convincing or is subject to error due to some methodological consideration, despite a nominally significant p value or important effect size (e.g., the condemnation of IMG carotid endarterectomy complication rates based on a trivial number of cases – Ann Intern Med 1990;113:747–753). | The approach to assigning SOE is summarized in the methods section. The summary table in the discussion presents our judgments about each domain (study design, risk of bias, consistency, directness, precision) that forms the foundation for these judgments.
6 | RE: RESULTS:
6 | I am surprised that there is no description of the eligibility criterion. Obviously, the DM trials required the patients to have DM, but there is no information about whether this was to be poorly controlled or of a certain duration, or if the patients had to have a stable medical regimen or be taking or not taking insulin or ?? | Thank you. We have added descriptions of the eligibility criteria to the results (see KQ 1).
6 | Outcomes are well reported in tabular form. Although there are no statistically effects by study or patient characteristics, I would have liked some exploration of individual examples with greater or smaller effect size, and some assessment of why one had more effect than another. | Effects were consistent for blood pressure outcomes but varied for glucose control and HRQOL. We explored three factors hypothesized a priori to be related to effect size: baseline severity, intervention robustness, and study quality.
6 | It is presumably because the study authors did not include the information, but one wonders if there are any process measures like medication changes or behavior changes that could explain the change in control. For example, with all the BP improvement, did this reflect a drop in weight, a change in prescribed medication, a change in medication adherence, a change in physical activity or what ? Or do we just not know? It seems most likely that this reflects a medication effect, since the effect on A1c, LDL and BP are all sensitive to this, and there is no evidence of a change in weight – I assume this was examined and will be reported in the revised version. | The authors of the individual studies did not provide this data consistently. A few studies report effects on self-management behaviors and these results are reported in KQ 1 “treatment experience and adherence outcomes.” We also abstracted information on medication changes and report these results in the same section
6 | RE: DISCUSSION:
6 | I love that there is an explicit paragraph labeled “Should SMAs be Implemented?” But I am disappointed that it does not appear that they answer this question. Since the VA in particular paid for this synthesis, one would think there would at least be an answer for VA. It might be something along the lines of “The evidence available suggests that the VA should be implementing an SMA in all hospitals. This should be made available for all patients who have inadequate control. However, one should require referral by the primary care provider.” One would obviously provide caveats and nuance the presentation, but it is unfortunate that when the explicit goal is to help policy makers change policy, the guidance is vague. | Our goal is to synthesize the evidence to inform policymaking. Although we try to describe some of the considerations (in addition to evidence of intervention effect) that might influence policy, it is not our role to prescribe policy.
6 | RE: APPENDIX C – DATA ELEMENTS ABSTRACTED
6 | Hard to imagine that weight was not abstracted from at least some of the studies, given that all the disease specific studies were about diabetes. | Weight was not specified as an outcome of interest by our study team or stakeholders.
6 | “Health professionals who conducted the educational session” is not reported with much specificity – that is, we see only MD as the descriptor. Is there evidence of specialists versus generalists? The same question applies to the pharmacists. Or are they just people who are interested in the area or researcher team members. | Specialty, training and experience of the MD professionals were almost never described.
6 | RE: APPENDIX G – Study characteristics of included studies The column labeled “Target condition HBA1c % (for total population)” appears to be mislabeled. The number in parentheses seems to be the standard deviation, not the value of A1c for the total population. Or the percent of the total population included – I am not sure what they mean by this. | Thank you. We relabeled the column to improve clarity.
6 | Usual care could have been described in more detail. Particularly in situations where the DM control was poor at baseline, one would imagine that the correct comparator would be some other, non-group approach to improved control – probably as simple as having the prescribing provider see the person for better control. | We have added a paragraph describing the Comparison Conditions in more detail in the “Study Characteristics” section of the results.
6 | Since the introduction suggests that access to an expert provider might be the mechanism of action, I wonder if there is information about the training of the MD or pharmacist. | Unfortunately, information about the specialty training and experience of the MD clinician or clinical pharmacist was give rarely.
7 | Other elements to assess in explaining heterogeneity of study results in diabetes is the clinician expertise in diabetes and group management, e.g. do the clinician(s) have training in diabetes or conduction of group visits prior to starting the trial – such as being a certified diabetes educator, do the clinician(s) manage diabetes in other settings – such as individual diabetes clinics, how many disciplines were in the team, etc. | Although this is a good idea, and could explain heterogeneity in intervention effects, clinician expertise and certification as a diabetes educator were not described consistently enough for analysis.

Optional Dissemination and Implementation Questions
Question 5: Are there any VA clinical performance measures, programs, quality improvement measures, patient care services, or conferences that will be directly affected by this report? If so, please provide detail.
1 | I do not work in the VA setting, so am unable to comment on this. | Acknowledged
2 | The Office of Nursing Service (ONS) conducts courses on EBP; use of this document may enhance learning for the participants who would attend this conference; given that the EBP course is for the properly targeted audience. | Acknowledged
2 | The other group that could benefit is the Clinical Practice Portfolio of the ONS as this ES is timely to impact recommendations for intervention for both PACT and Specialty Care services. In addition, a presentation on the findings would be beneficial for the Advanced Practice Nursing Advisory Group as this group of providers would be influenced by these findings. | Acknowledged
3 | PACT compass, Office of Patient Care Service, Office of Nursing Service, Office of Academic Affiliations: Centers of Excellence in Primary Care Education | Acknowledged
4 | PACT implementation included an emphasis on SMA and group visits as a means to enhance access and implement a chronic care model. | Acknowledged
4 | The ability to improve access is not addressed by this data synthesis. A SMA of reasonable size might improve access by reducing reliance on routine clinic visits. This hypothesis was not evaluated. A concern from the perspective of PACT is that the SMA might adversely affect patient continuity with their primary care provider. The information regarding whether the intervention preserved patient continuity with the provider or not is not provided. An evaluation of the benefits of SMA versus the trade-offs might ultimately be very helpful. | Most studies describe the intervention as additional care, rather than a substitute for primary care. We have added a statement to this effect in the discussion. No studies reported access outcomes directly or information on continuity with their PCP. Few reported effects on patient experience.
5 | PACT initiative in Primary Care is promoting SMA’s. | Acknowledged
6 | The authors are clear that there is not enough evidence that we can say that use or non-use of SMA is a quality issue. I think there are a number of conferences where the results will be of interest – certainly HSR and QUERI and hopefully the leadership meetings. | The results of this review and a parallel “realist” review are being presented at the July 2012 HSR&D conference.
7 | PACT compass that includes SMA as one of its components, in addition to the traditional diabetes performance measures in Primary care | Acknowledged
Question 6: Please provide any recommendations on how this report can be revised to more directly address or assist implementation needs.
1 | No comments by reviewer 2
2 | Report is very well done. Are companion presentations done in conjunction with the report (PowerPoint, to be used for presenting to interested groups)? | Thank you. There will be a presentation at the July 2012 HSR&D/QUERI meeting.
3 | Executive summary very direct and to the point. Recommendations for future research offer usable directions | Thank you.
4 | More information about the intervention would have been helpful. Key elements that may result in successful implementation are hinted at in Table 6, but are not fully discussed. This table is also not self-explanatory: for example what is meant by “Team continuity”? | We revised Table 6 and footnoted other tables to more improve clarity. Detailed information on the intervention is presented in Appendix H and summarized in Table 3.
5 | A table of the roles of each providers (along with quality) in the studies would help as sites try to implement SMA’s | Although team composition was described, roles of individual providers were not described consistently enough to develop the requested table.
6 | See response to #4 | Addressed above.
7 | I believe this report is an unbiased assessment and synthesis of current literature and clearly points out the strengths and weaknesses of the available data | Thank you.
Question 7: Please provide us with contact details of any additional individuals/stakeholders who should be made aware of this report.
1 | No. No comment | Acknowledged
2 | Once completed: Christine Engstrom, Anna Alt-White | Acknowledged
3 | PACT e-mail group, Centers of Excellence in Primary Care Education | Acknowledged
4 | Richard Stark; Joanne Shear | Acknowledged
5 | No comment | Acknowledged
6 | None in particular | Acknowledged
7 | No comment | Acknowledged