# DATA ABSTRACTION ELEMENTS

Study Characteristics:

- Study Sites and Setting
- Study Design
- Comparator Type
- Enrollment Approach
- Study Enrollment/Study Completion (N’s)
- Patient Eligibility Criteria for Study

Population Characteristics:

- Demographic
- Baseline Biophysical Characteristics

Intervention Components:

- Time period of intervention
- Type of model session and care team
- Number and duration of visits planned
- Number of health professionals present
- Was the prescribing clinician present?
- Size of patient group
- Were family members/friends invited to participate?
- Were medication changes made during the SMA visit?
- Did any clinician spend time with group members individually?
- Was the contact with the patients over the telephone outside of the SMA?
- Health professionals who conducted the educational session
- Theoretical orientation of the intervention
- Did group member have input on education topics?
- Topics covered during the session
- Strategy used with SMA group
- Were printed materials provided, and were they tailored?

Outcome Components:

- Target conditions
  ○ Biophysical markers postintervention values
    ■ HbA1c
    ■ Blood Pressures
    ■ Lipids
- Patient and staff experience
- Adherence (medication, visit, and self-management)
- Symptom severity
- Quality of life
- Functional status
- Resource utilization
- Direct cost and total cost
- Adverse effects