# EXCLUDED STUDIES

All articles listed below were reviewed in their full-text version and excluded for the reason indicated. An alphabetical reference list follows the table.

Table B-1 Excluded studies with reasons

Reference | Not full publication, peer-reviewed, or primary data | Not study population of interest | Not eligible study design | Comparator not of interest | Intervention does not meet protocol definition | Not an outcome of interest reported at ≥3 months
AHRQ, 2003 (943) | X
AHRQ, 2007 (844) | X
Anonymous, 1996 (946) | X
Anonymous, 2001 (913) | X
Anonymous, 2001 (944) | X
Anonymous, 2003 (351) | X
Antonucci, 2008 (835) | X
Barud, 2006 (730) | | | X
Block, 2010 (747) | X
Bray, 2005 (299) | | | X
Bronson, 2004 (1331) | | | X
Brooks, 2007 (265) | | | X
Campbell, 2007 (518) | | X
Clancy, 2003 (347) | | | | | | X
Clancy, 2007 (259) | | | | | | X
Conrad, 2008 (775) | | X
Desouza, 2010 (157) | | | X
Anonymous, 2001 (373) | X
Dontje, 2011 (607) | | | X
Falck-Ytter, 2009 (1286) | X
Geller, 2011 (142) | | | X
Harris, 2010 (178) | | X
Jaber, 2006 (780) | X
Jeanfreau, 2008 (732) | X
Anonymous, 2002 (955) | X
Katz, 1975 (596) | X
Kirsh, 2006 (1312) | X
Krywkowski-Mohn, 2009 (1508) | X
Lin, 2008 (214) | | | X
Loney-Hutchinson, 2009 (703) | | | X
Mackay, 2011 (649) | | X
Masley, 2001 (386) | | | | | X
Mayo Clinic Proceedings, 2008 (507) | | | | | X
McCulloch, 1998 (410) | | | X
McHugh, 1998 (420) | | | | | X
Miller, 329 (329) | | | X
Murray, 2005 (313) | X
Ostroff, 2010 (1278) | X
Palaniappan, 2011 (135) | | X
Peterson, 2007 (929) | X
Porta, 2004 (326) | | | | | | X
Reiber, 2004 (328) | | | | | X
Rivard, 2009 (498) | X
Rossi, 2011 (1269) | X
Salinas, 2006 (1308) | X
Salinas-Martinez, 2009 (1282) | X
Sanchez, 2011 (608) | | | X
Scott, 1998 (426) | X
Shahady, 2008 (795) | X
Shahady, 2010 (465) | X
Stoner, 2001 (375) | | | | | X
Taveira, 2008 (1686) | | | X
Thompson, 2000 (875) | X
Thompson, 2001 (389) | | X
Trento, 2006 (291) | | | | | | X
Trento, 2008 (1291) | X
Trento, 2008 (238) | | | | | | X
Trento, 2009 (1283) | X
Trento, 2009 (1284) | X
Trento, 2009 (904) | | | | X
Vachon, 2007 (237) | | | X
Vinci, 2006 (1311) | X
Watkinson, 2004 (976) | X
Watts, 2009 (1582) | | | X
Weber, 2004 (1333) | X
Westheimer, 2009 (666) | | | X
Wheelock, 2009 (211) | | | X
Worth, 1990 (557) | | | | | X
Yehle, 2007 (689) | X
Yehle, 2009 (213) | | | | | | X
Yu, 2010 (165) | | | | | X

## LIST OF EXCLUDED STUDIES

Agency for Healthcare Research and Quality. Group visits to primary care doctors by disadvantaged diabetes patients result in better diabetes care than individual visits. AHRQ Research Activities. 2003;(278):14-14.
Agency for Healthcare Research and Quality. Studies examine medication adherence and group medical visits among persons with high blood pressure. AHRQ Research Activities. 2007;(326):16-17.
Colorado HMO trades traditional doctor visits for group clinics. Disease State Management. 1996;2(2):13-17.
DIGMAs (drop-in group medical appointments): satisfaction Rx for doctors and patients. Hosp Peer Rev. 2001;26(6):81-2. [pmid: 11419256].
Researchers find new value in group visit concept among chronically ill adults. Disease Management Advisor. 2001;7(8):121-125. [pmid: 11530658].
Take steps to ensure group visits are successful: start with chronic patient groups. Patient Education Management. 2001;8(8):92.
Group appointments for seniors continue to prove their worth. Senior Care Management. 2002;5(4):57-59.
Shared medical appointments save money for capitated groups. Capitation Manag Rep. 2003;10(2):20-4. 17. [pmid: 12635482].
Antonucci J. A new approach to group visits: helping high-need patients make behavioral change. Fam Pract Manag. 2008;15(4):A6-8. [pmid: 18444311].
Barud S, Marcy T, Armor B, et al. Development and implementation of group medical visits at a family medicine center. Am J Health Syst Pharm. 2006;63(15):1448-1452. [pmid: 16849711].
Block JP. Outcomes research in review. Group visits for the treatment of hypertension among diabetics: success without a pill?. Journal of Clinical Outcomes Management. 2010;17(8):343.
Bray P, Roupe M, Young S, et al. Feasibility and effectiveness of system redesign for diabetes care management in rural areas: the eastern North Carolina experience. Diabetes Educ. 2005;31(5):712-8. [pmid: 16203855].
Bronson DL, Maxwell RA. Shared medical appointments. Increasing patient access without increasing physician hours. Cleve Clin J Med. 2004;71(5):369-+. [pmid: 15195773].
Brooks AD, Rihani RS, Derus CL. Pharmacist membership in a medical group’s diabetes health management program. Am J Health Syst Pharm. 2007;64(6):617-21. [pmid: 17353570].
Campbell BB, Gosselin D. High patient satisfaction amongst males participating in men’s educational group appointments (MEGA) for routine physical exams. Journal of Men’s Health and Gender. 2007;4(3):266-270.
Clancy DE, Cope DW, Magruder KM, et al. Evaluating group visits in an uninsured or inadequately insured patient population with uncontrolled type 2 diabetes. Diabetes Educ. 2003;29(2):292-302. [pmid: 12728756].
Clancy DE, Yeager DE, Huang P, et al. Further evaluating the acceptability of group visits in an uninsured or inadequately insured patient population with uncontrolled type 2 diabetes. Diabetes Educ. 2007;33(2):309-14. [pmid: 17426306].
Conrad D, Fishman P, Grembowski D, et al. Access intervention in an integrated, prepaid group practice: effects on primary care physician productivity. Health Serv Res. 2008;43(5 Part 2):1888-1905. [pmid: 18662171].
Desouza CV, Rentschler L, Haynatzki G. The effect of group clinics in the control of diabetes. Prim Care Diabetes. 2010;4(4):251-4. [pmid: 20947460].
Dontje K, Forrest K. Implementing Group Visits: Are They Effective to Improve Diabetes Self- Management Outcomes?. Journal for Nurse Practitioners. 2011;7(7):571-577.
Falck-Ytter CD, Ellert R, Denise K, et al. Effect of a Diabetes Group Clinic Using Shared Medical Visits on Outcomes for Diabetic Patients Cared for in an Urban Resident Clinic. J Gen Intern Med. 2009;24:252-252. [pmid: 19089501].
Geller JS, Orkaby A, Cleghorn GD. Impact of a group medical visit program on Latino health-related quality of life. Explore (NY). 2011;7(2):94-9. [pmid: 21397870].
Harris MD. Shared medical appointments after cardiac surgery-the process of implementing a novel pilot paradigm to enhance comprehensive postdischarge care. J Cardiovasc Nurs. 2010;25(2):124-9. [pmid: 20168192].
Jaber J, Braksmajer A, Trilling J. Group Visits for Chronic Illness Care: Models, Benefits and Challenges. Fam Pract Manag. 2006;13(1):37-40. [pmid: 16457463].
Jeanfreau S. Group visit intervention to improve diabetes care -- a program utilizing group visits led by a nurse practitioner to improve outcomes for the medically underserved in diabetes care. Southern Online Journal of Nursing Research. 2008;8(2):2p.
Katz G, Hollander FL. From clinic to group practice. Hospitals. 1975;49(5):67-71. [pmid: 1089596].
Kirsh S, Watts S, Aron D, et al. Integrating residency training and diabetes shared medical appointments. J Gen Intern Med. 2006;21:74-75.
Krzywkowski-Mohn SM. Diabetic control and patient perception of the scheduled in group medical appointment at the Cincinnati veterans administration medical center. ProQuest Information & Learning. 2009.
Lin A, Cavendish J, Boren D, et al. A pilot study: reports of benefits from a 6-month, multidisciplinary, shared medical appointment approach for heart failure patients. Mil Med. 2008;173(12):1210-3. [pmid: 19149341].
Loney-Hutchinson LM, Provilus AD, Jean-Louis G, et al. Group visits in the management of diabetes and hypertension: effect on glycemic and blood pressure control. Current Diabetes Reports. 2009;9(3):238-242. [pmid: 19490826].
Mackay FD. Well Woman’s Group Medical Appointment: For screening and preventive care. Can Fam Physician. 2011;57(4):e125-7. [pmid: 21490343].
Masley S, Phillips S, Copeland JR. Group office visits change dietary habits of patients with coronary artery disease-the dietary intervention and evaluation trial (D.I.E.T.). J Fam Pract. 2001;50(3):235-9. [pmid: 11252212].
Mayo Clinic Proceedings. Chronic care model and shared care in diabetes: Randomized trial of an electronic decision support system. (Mayo Clinic Proceedings (2008) 83, 7, (747–757)). Mayo Clin Proc. 2008;83(10):1189.
McCulloch DK, Price MJ, Hindmarsh M, et al. A population-based approach to diabetes management in a primary care setting: early results and lessons learned. Eff Clin Pract. 1998;1(1):12-22. [pmid: 10345254].
McHugh F, Lindsay G. A study of nurse-led shared care for coronary patients. Nurs Stand. 1998;12(45):33. [pmid: 9752139].
Miller D, Zantop V, Hammer H, et al. Group medical visits for low-income women with chronic disease: a feasibility study. J Womens Health (Larchmt). 2004;13(2):217-25. [pmid: 15072736].
Murray JL, Everson K. Group medical visits and lifestyle modifications. J Fam Pract. 2005;54(1):64. [pmid: 15623409].
Ostroff ABM, Sundel S, Bradley S, et al. Group Visits: A Model to Improve Patient Self-Management in Geriatric Ambulatory Practice. J Am Geriatr Soc. 2010;58:228-228.
Palaniappan LP, Muzaffar AL, Wang EJ, et al. Shared medical appointments: promoting weight loss in a clinical setting. J Am Board Fam Med. 2011;24(3):326-8. [pmid: 21551406].
Peterson C, Chicano K, Capone-Swearer D, et al. Shared medical appointments. Nurse Practitioner World News. 2007;12(6):16-16.
Porta M, Trento M. ROMEO: rethink organization to improve education and outcomes. Diabet Med. 2004;21(6):644-5. [pmid: 15154956].
Reiber GE, Au D, McDonell M, et al. Diabetes quality improvement in Department of Veterans Affairs Ambulatory Care Clinics: a group-randomized clinical trial. Diabetes Care. 2004;27(Suppl 2):B61-8. [pmid: 15113785].
Rivard L, Walker C, Arias A, et al. Group medical visits achieve improvements of clinical outcomes in diverse ethnic, underinsured populations: A project dulce(trademark) disease management intervention. Diabetes. 2009;58.
Rossi AM, Tucker AL, Hedelt AC. Cardiovascular Disease Prevention Tailored for Women: Shared Medical Appointments. J Cardiovasc Nurs. 2011;26(4):276-277.
Salinas AM, Irizar JF, Garza MG, et al. The cluster visit along with all-inclusive management: A good plan for improving diabetes primary care effectiveness?. Diabetes. 2006;55:A552-A552.
Salinas-Martinez AM, Garza-Sagastegui MG, Cobos-Cruz R, et al. Effects of incorporating group visits on the metabolic control of type 2 diabetic patients. Rev Med Chil. 2009;137(10):1323-1332. [pmid: 20011939].
Sanchez I. Implementation of a Diabetes Self-management Education Program in Primary Care for Adults Using Shared Medical Appointments. Diabetes Educ. 2011;37(3):381-391. [pmid: 21454887].
Scott J, Gade G, McKenzie M, et al. Cooperative health care clinics: a group approach to individual care. Geriatrics. 1998;53(5):68-70. 76. 8. 81. quiz 82. [pmid: 9597981].
Shahady EJ. Diabetes management: an approach that improves outcomes and reduces costs. Consultant (00107069). 2008;48(4):331.
Shahady EJ. Group visits for diabetes: An innovative way to overcome barriers and achieve quality care. Cons_ltant. 2010;50(11).
Stoner KL, Lasar NJ, Butcher MK, et al. Improving glycemic control: can techniques used in a managed care setting be successfully adapted to a rural fee-for-service practice?. Am J Med Qual. 2001;16(3):93-8. [pmid: 11392175].
Taveira TH, Pirraglia PA, Cohen LB, Wu WC. Efficacy of a pharmacist-led cardiovascular risk reduction clinic for diabetic patients with and without mental health conditions. Prev Cardiol. Fall. 2008;11(4):195-200. [pmid: 19476571].
Thompson E. Physicians. The power of group visits: improved quality of care, increased productivity entice physicians to see up to 15 patients at a time. Mod Healthc. 2000;30(23):54. [pmid: 11183494].
Thompson M, Gee S, Larson P, et al. Health and loyalty promotion visits for new enrollees: results of a randomized controlled trial. Patient Educ Couns. 2001;42(1):53-65. [pmid: 11080606].
Trento M. ROMEO (Rethink Organization to iMprove Education and Outcomes). A 4-year multicentre randomised controlled trial of group care for the management of type 2 diabetes. Diabetologia. 2008;51:S69-S69.
Trento M, Passera P, Bajardi M, et al. Lifestyle intervention by group care prevents deterioration of Type II diabetes: a 4-year randomized controlled clinical trial. Diab tologia. 2002;45(9):1231-9.
Trento M, Passera P, Miselli V, et al. Evaluation of the locus of control in patients with type 2 diabetes after long-term management by group care. Diabetes Metab. 2006;32(1):77-81. [pmid: 16523190].
Trento M, Porta M. Romeo (Rethink Organization to Improve Education and Outcomes). A 4-Year Multicentre Randomised Controlled Trial of Group Care for the Management of Type 2 Diabetes. Atherosclerosis Supplements. 2009;10(2).
Trento M, Sicuro J, Semperbene L, et al. Cost-efficacy of group care in the management of type 2 diabetes. Economic evaluation of the ROMEO (Rethink Organization to iMprove Education and Outcomes) data set. Diabetologia. 2009;52:S391-S391.
Trento M, Tomelini M, Basile M, et al. The locus of control in patients with Type 1 and Type 2 diabetes managed by individual and group care. Diabet Med. 2008;25(1):86-90. [pmid: 18199135].
Vachon GC, Ezike N, Brown-Walker M, et al. Improving access to diabetes care in an inner-city, community-based outpatient health center with a monthly open-access, multistation group visit program. J Natl Med Assoc. 2007;99(12):1327-36. [pmid: 18229769].
Vinci LM, Clark J, Buchholz N, et al. Improving diabetes care with nurse practitioner-led group visits and simple case management. J Gen Intern Med. 2006;21:72-72.
Watkinson M. Group visits improved concordance with American Diabetes Association practice guidelines in type 2 diabetes. Evidence Based Nursing. 2004;7(2):57-57. [pmid: 15106639].
Watts SA, Gee J, O’Day ME, et al. Nurse practitioner-led multidisciplinary teams to improve chronic illness care: The unique strengths of nurse practitioners applied to shared medical appointments/group visits. J Am Acad Nurse Pract. 2009;21(3):167-172. [pmid: 19302693].
Weber V, Bulger J, Sim J. Implementing a group visit model for adult patients with diabetes: A pilot. J Gen Intern Med. 2004;19:105-106.
Westheimer JM, Capello J, McCarthy C, et al. Employing a group medical intervention for hypertensive male veterans: an exploratory analysis. Journal for Specialists in Group Work. 2009;34(2):151-174.
Wheelock C, Savageau JA, Silk H, et al. Improving the health of diabetic patients through resident-initiated group visits. Fam Med. 2009;41(2):116-9. [pmid: 19184689].
Worth RC, Nicholson A, Bradley P. Shared care for diabetes in Chester: Preliminary experience with a ‘clinic-wide’ scheme. Practical Diabetes. 1990;7(6):266-268.
Yehle KS. A comparison of standard office visits and shared medical appointments in adults with heart failure. Touro University International. 2007.
Yehle KS, Sands LP, Rhynders PA, et al. The effect of shared medical visits on knowledge and self-care in patients with heart failure: a pilot study. Heart Lung. 2009;38(1):25-33. [pmid: 19150528].
Yu GC, Beresford R. Implementation of a chronic illness model for diabetes care in a family medicine residency program. J Gen Intern Med. 2010;25(Suppl 4):S615-9. [pmid: 20737237].