# SEARCH STRATEGIES

Table A-1 Search strategy for RCTs and observational studies (PubMed, April 2012)

Step | Category | Terms | Result
1 | Terms for “group appointment” | (visit[ti] OR visits[ti] OR appointment[ti] OR appointments[ti] OR clinic[ti] OR clinics[ti] OR “Appointments and Schedules”[Mesh]) AND (group[ti] OR shared[ti] OR cluster[ti]) | 744
2 | Terms for “shared visits” | (“shared medical appointment”[tiab] OR “shared medical appointments”[tiab] OR “group care”[tiab] OR “group medical appointment”[tiab] OR “group medical appointments”[tiab] OR “cluster visit”[tiab] OR “cluster visits”[tiab] OR “group visit”[tiab] OR “group visits”[tiab] OR “shared medical visit”[tiab] OR “shared medical visits”[tiab] OR “group medical clinic”[tiab] OR “group medical clinics”[tiab]) | 313
3 | Combined intervention terms | #1 OR #2 | 961
4 | Terms for RCT study design | (randomized controlled trial[pt] OR controlled clinical trial[pt] OR randomized[tiab] OR randomised[tiab] OR randomization[tiab] OR randomisation[tiab] OR placebo[tiab] OR drug therapy[sh] OR randomly[tiab] OR trial[tiab] OR groups[tiab] OR Clinical trial[pt] OR “clinical trial”[tw] OR “clinical trials”[tw] OR “evaluation studies”[Publication Type] OR “evaluation studies as topic”[MeSH Terms] OR “evaluation study”[tw] OR evaluation studies[tw] OR “intervention studies”[MeSH Terms] OR “intervention study”[tw] OR “intervention studies”[tw] OR “cohort studies”[MeSH Terms] OR cohort[tw] OR “longitudinal studies”[MeSH Terms] OR “longitudinal”[tw] OR longitudinally[tw] OR “prospective”[tw] OR prospectively[tw] OR “follow up”[tw] OR “comparative study”[Publication Type] OR “comparative study”[tw] OR systematic[subset] OR “meta-analysis”[Publication Type] OR “meta-analysis as topic”[MeSH Terms] OR “meta-analysis”[tw] OR “meta-analyses”[tw]) NOT (Editorial[ptyp] OR Letter[ptyp] OR Case Reports[ptyp] OR Comment[ptyp]) NOT (animals[mh] NOT humans[mh]) | 4216173
5 | Intervention AND RCT | #3 AND #4 | 466
6 | Terms for observational studies | “pre-post”[tiab] OR “post-test”[tiab] OR “post test”[tiab] OR pretest[tiab] OR pre-test[tiab] OR “pre test”[tiab] OR quasi-experiment*[tiab] OR quasiexperiment*[tiab] OR quasirandom*[tiab] OR quasi-random*[tiab] OR quasi-control*[tiab] OR quasicontrol*[tiab] OR (“time series”[tiab] AND interrupt[tiab]) OR (“time points”[tiab] AND (multiple[tiab] OR one[tiab] OR two[tiab] OR three[tiab] OR four[tiab] OR five[tiab] OR six[tiab] OR seven[tiab] OR eight[tiab] OR nine[tiab] OR ten[tiab] OR month*[tiab] OR day*[tiab] OR week*[tiab] OR hour*[tiab]) OR (before[tiab] AND after[tiab]) OR (*before[tiab] AND during[tiab]) | 44225
7 | Intervention and Observational | #3 AND #6 | 11
8 | Applies limits to combined RCT and observational studies | #5 OR #7 with limits: English, Publication Date from 1996 to 2011 | 323