# SUMMARY AND DISCUSSION

Findings from high-quality systematic reviews describe potential benefits of massage for pain indications including labor, shoulder, neck, back, cancer, fibromyalgia, and temporomandibular disorder. However, no findings were rated as moderate- or high-strength, indicating that more research is needed to establish confidence in the effect of massage for pain. A third of included reviews did not meet our threshold for high quality. While some of these reviews overlapped in scope with higher quality reviews, others did not, and these topics need to be revisited with strong synthesis methodology before conclusions can be drawn from the findings.

Systematic review authors found that primary studies often do not provide adequate details of the massage therapy provided, especially in the descriptions of provider type. In addition, terminology is unclear, with no standardized definition of massage types or what specific therapies are included under the umbrella term “massage.”

## FUTURE WORK

This evidence mapping process was intended to describe the range of evidence on massage for pain. When multiple systematic reviews within the evidence map overlap in pain indications, cross-checking of these reviews may be necessary to determine if the same primary studies are being described, the extent of the overlap, and applicability of some or all findings in a review for a particular research or policy question. In one such example, fibromyalgia systematic reviews had differing findings, with 2 of lower quality. A future synthesis would be needed to see which studies were included in all reviews, and which were included in some but not others to determine a new finding inclusive of all potential evidence. The topics with multiple bubbles, especially with differing findings, may be areas that are ripe for an update systematic review. Other areas where future synthesis efforts would be beneficial include updating pain indications for which existing reviews are outdated (eg, critical care).