# RESULTS

## LITERATURE FLOW

Our searches identified 4,568 titles as potentially relevant for this evidence map. From these titles, 246 references were included for abstract review. Our screen of abstracts excluded 196 abstracts because they did not mention pain as an outcome, did not mention massage as an intervention, used a study design other than systematic review, or some combination of these factors. When reviewing full texts, there were 13 references that did not meet inclusion criteria upon further inspection. In 3 publications, the results for massage were not reported separately from other interventions, 3 publications were only available in abstract form, 2 were systematic reviews of systematic reviews, 2 were non-systematic reviews, 2 were not retrievable, and one was a duplicate of another included publication. See the Literature Flow in Figure 1.

Figure 1 Literature Flow Chart

* Results from searches described in Appendix A

** Manuscript reference list includes additional references cited for background and methods.

From the 50 references included in the full-text review, we included 37 references that discuss 31 systematic reviews. Six references discussed systematic reviews that were duplicative of included systematic reviews.^20-25^ This includes older iterations of Cochrane systematic reviews, the updates for which had been included,^20,21^ as well as instances where multiple publications were produced from the same systematic review effort.^22-25^

## QUALITY OF INCLUDED SYSTEMATIC REVIEWS

Of the 31 systematic reviews included, 6 reviews met all 11 modified AMSTAR criteria (see Table 1). Seven reviews met 10 of the criteria, and 8 reviews met 9 of the criteria. These 21 systematic reviews were considered high quality and account for 67.7 percent of the included reviews. The other 10 systematic reviews were of lower quality, receiving credit for 8 criteria (n=3), 7 criteria (n=2), 6 criteria (n=3), 5 criteria (n=1), or 3 criteria (n=1) in the AMSTAR quality assessment. All 31 systematic reviews provided the characteristics of their included studies, which was the only criterion met by all included systematic reviews in this evidence map. The least often-met criterion was to provide an a priori design, with 11 systematic reviews meeting this criterion.

Table 1 Modified AMSTAR Scoring for Included Systematic Reviews

| A priori design provided | Duplicate review | Comprehensive search | Status of publication used | List of studies included | Included study characteristics | Assessed quality of includes | Quality used in conclusions | Synthesis methods appropriate | Publication bias assessed | Include conflict of interest | Total Score
Anthonissen 2016 | ? | Yes | Yes | Yes | Yes | Yes | Yes | Yes | Yes | Yes | Yes | 10
Piper 2016 | Yes | Yes | Yes | Yes | Yes | Yes | Yes | Yes | Yes | No | Yes | 10
Furlan 2015 | Yes | Yes | Yes | Yes | Yes | Yes | Yes | Yes | Yes | Yes | Yes | 11
Bervoets 2015 | ? | Yes | Yes | Yes | Yes | Yes | Yes | Yes | Yes | No | Yes | 9
Calixtre 2015 | ? | Yes | Yes | Yes | Yes | Yes | Yes | No | Yes | Yes | Yes | 9
Keeratitanont 2015 | No | ? | Yes | No | Yes | Yes | Yes | Yes | N/A | No | Yes | 6
Yuan 2015 | Yes | Yes | Yes | No | Yes | Yes | Yes | Yes | Yes | No | No | 8
Loew 2014 | Yes | Yes | Yes | Yes | Yes | Yes | Yes | Yes | Yes | Yes | Yes | 11
Chaibi 2014 | No | No | Yes | Yes | Yes | Yes | Yes | Yes | ? | ? | Yes | 7
Cheng 2014 | No | Yes | Yes | Yes | Yes | Yes | Yes | Yes | Yes | ? | No | 8
Li 2014 | ? | Yes | Yes | Yes | Yes | Yes | Yes | Yes | Yes | Yes | Yes | 10
Kong 2013 | ? | Yes | Yes | Yes | Yes | Yes | Yes | Yes | Yes | Yes | Yes | 10
Patel 2012 | Yes | Yes | Yes | Yes | Yes | Yes | Yes | No | Yes | Yes | Yes | 10
van den Dolder 2014 | Yes | Yes | Yes | Yes | Yes | Yes | Yes | Yes | No | ? | Yes | 9
Smith 2012 | Yes | Yes | Yes | Yes | Yes | Yes | Yes | Yes | Yes | Yes | Yes | 11
Terhorst 2011 | No | Yes | Yes | Yes | Yes | Yes | Yes | Yes | Yes | ? | Yes | 9
Furlan 2010 | Yes | Yes | Yes | Yes | Yes | Yes | Yes | Yes | Yes | Yes | Yes | 11
Ernst 2009 | No | ? | Yes | Yes | Yes | Yes | Yes | Yes | Yes | ? | No | 7
Wilkinson 2008 | ? | Yes | Yes | Yes | Yes | Yes | Yes | Yes | Yes | Yes | Yes | 10
Ezzo 2007 | ? | Yes | Yes | ? | Yes | Yes | Yes | Yes | Yes | ? | Yes | 8
Bardia 2006 | Yes | Yes | Yes | Yes | Yes | Yes | Yes | Yes | Yes | Yes | Yes | 11
Smith 2006 | Yes | Yes | Yes | Yes | Yes | Yes | Yes | Yes | No | ? | Yes | 9
Haraldsson 2006 | Yes | Yes | Yes | Yes | Yes | Yes | Yes | Yes | Yes | Yes | Yes | 11
Huntley 2004 | ? | Yes | Yes | Yes | Yes | Yes | Yes | Yes | Yes | Yes | Yes | 10
Cherkin 2003 | ? | Yes | Yes | Yes | Yes | Yes | Yes | ? | Yes | Yes | Yes | 9
Simkin 2002 | ? | Yes | Yes | Yes | Yes | Yes | Yes | Yes | Yes | Yes | No | 9
Pan 2000 | ? | Yes | Yes | Yes | Yes | Yes | ? | ? | ? | ? | Yes | 6
Richards 2000 | No | ? | Yes | Yes | Yes | Yes | Yes | ? | ? | ? | No | 5
Ernst 1999 | ? | ? | Yes | Yes | Yes | Yes | ? | No | Yes | Yes | No | 6
Kong 2011 | No | ? | ? | ? | No | Yes | Yes | Yes | ? | ? | No | 3
Lewis 2006 | ? | Yes | Yes | Yes | Yes | Yes | Yes | Yes | Yes | ? | Yes | 9

? = cannot determine based on description provided; N/A = not applicable in this publication; full criteria are described in Appendix B.

## EVIDENCE MAP

The results of the evidence mapping process are depicted visually in the evidence map (Figure 2), as well as described narratively. The evidence map displays each of the 31 included systematic reviews as bubbles. The bubble label represents the pain indication described in that review. The bubble size denotes the number of primary studies included in that review specifically related to massage for pain. Primary studies may be included in multiple systematic reviews. Each of these bubbles is plotted according to the strength of the findings for massage for pain (y-axis), as well as by the effect massage was found to have for pain (x-axis). The evidence tables provide details of included systematic reviews (Appendix D).

Figure 2 Evidence Map of Systematic Reviews Describing the Effect of Massage for Pain

LBP = low back pain, TMJ = temporomandibular disorder; Multi = multiple conditions described

## FINDINGS FROM SYSTEMATIC REVIEWS IN THE EVIDENCE MAP

### Findings from High-quality Systematic Reviews

The findings from the 21 high-quality systematic reviews were categorized according to strength of findings, with no systematic reviews describing moderate- or high- strength findings. No systematic reviews found massage to be worse than the comparator.

Of the 6 systematic reviews describing low-strength findings, 3 reviews found that massage was potentially better than the comparator. The first systematic review included 6 trials, all of which were describing the use of massage for pain during labor. This Cochrane review found that compared to usual care, massage during the first stage of labor was associated with less pain in the pooled results from 4 trials of 225 women (standardized mean difference -0.82, 95% CI: -1.17, -0.47). Overall, the authors found that massage may reduce pain during labor, but none of the included trials were completely at a low risk of bias for all quality domains and data were available for 326 women total, so our research team assigned their finding at low strength of evidence. The next systematic review aimed to determine the effectiveness of exercise and soft-tissue massage, either individually or in combination, when used to treat shoulder pain, and 7 of the 23 included publications were relevant to massage for pain. Their findings included studies using massage alone, as well as with combinations of treatments. They concluded that there is low-quality evidence supporting the effectiveness of massage for shoulder pain, when compared to no treatment or active controls like hot packs or short wave diathermy. All included studies had small sample sizes. The final systematic review with low-strength findings suggested that massage may be beneficial described the effectiveness of soft-tissue therapies for multiple conditions, including carpal tunnel syndrome, lateral epicondylitis, subacromial impingement syndrome, and plantar fasciitis. They found 6 studies with low risk of bias that suggested that overall, various types of massage may be effective for the musculoskeletal disorders and injuries of the lower extremities, however for each comparison identified, a single randomized controlled trial served as the source of information.

Three high-quality systematic reviews found mixed results, when massage sometimes performed better than the comparator, with low-strength findings. Two reviews were authored by Furlan and colleagues, with one focused on massage for low back pain and the other looking more broadly at complementary and alternative medicine for back and neck pain. These were the 2 of the 3 largest systematic reviews included in this evidence map, with 25 RCTs and 35 studies included, respectively. Both met all AMSTAR criteria, and described a number of detailed findings relevant to massage for pain for different pain types (eg, acute, subacute, chronic), follow-up periods, and comparators. Both grouped the comparison groups into 2 types: inactive controls that are not expected to improve outcomes (eg, sham therapy, waiting list, or no treatment), and active controls that are intended to improve outcomes (eg, manipulation, mobilization, acupuncture, traction, relaxation, physical therapy, exercises, pain medication, or self-care education). Massage for low back pain performed better than both active and inactive comparators in the short-term follow-up, but only compared to active comparators in the long-term follow-up. No difference was found between massage and inactive controls for long-term follow-up. Furlan and colleagues rated the strength of this evidence as low or very low due to the small sample sizes and methodological issues of the RCTs included in this Cochrane review. In their other review, massage was found to be superior to inactive comparators for acute and sub-acute low back pain, superior to active comparators for back pain, and superior to both active and inactive comparators for neck pain. For patients with nonspecific chronic low back pain, massage did not differ from inactive comparators but compared to active controls it performed significantly better in 2 meta-analyses. Massage for neck pain performed better than inactive comparators. These findings were ranked by their authors as mostly low strength. The final review in this group examined a range of conservative treatments, of which massage was one, for burn scars. Two of the 22 studies included in this systematic review were relevant to massage for pain, and both reported reductions in pain in the massage groups. These studies were small, and there were variations in massage techniques and populations, so we ranked this finding as low strength.

Five systematic reviews found very low-strength findings suggesting that massage may be better than the comparator for a variety of conditions. According to the GRADE approach, very low strength means there is “very little confidence in the effect estimate. The true effect is likely to be substantially different from the estimate of effect. Any estimate of effect is very uncertain.”^19^ So while these 5 reviews had positive findings, there is very little confidence in these positive effects. All 5 systematic reviews reported positive findings, but our research team assigned a very low strength, using the GRADE approach to all of them.

For fibromyalgia pain, massage therapy was reported in all 9 RCTs identified by Li and colleagues. Six of these were included in a meta-analysis that found nonsignificant reductions in pain, but the 3 RCTs reporting on massage with a duration 5 weeks or longer did show significant reductions in a subgroup analysis (SMD: 0.62; 95% CI: 0.05, 0.1.2; p=0.03). We rated this finding as very low strength. The second systematic review found very low strength of evidence from 8 small studies that manual therapies, including massage, improve pain in subjects with temporomandibular disorder. The third systematic review focused solely on massage for neck and shoulder pain and found 12 studies, 10 of which were RCTs that were included in the meta-analyses. Pooled outcomes showed significant immediate effects compared to inactive therapies (ie, waiting list control, standard care, and sham therapies) for both shoulder and neck pain (SMD: 1.79; 95% CI: 1.01, 2.57 and SMD: 1.5; 95% CI: 0.55, 2.45 respectively), and nonsignificant positive effects compared to active therapies (eg, acupuncture, traction, physical therapy, exercise, and activator trigger point therapy) for both shoulder and neck pain. The fourth systematic review assessed the evidence for massage for cancer symptom relief, with 4 of the 10 included studies reporting pain outcomes. These 4 studies suggested that pain improved with massage for patients with cancer, however the authors note that despite statistically significant findings in individual studies, the poor methodological quality and small sample sizes necessitate cautious interpretation of the findings. The final systematic review in this group summarized the evidence for complementary and alternative medicine for back pain, with 8 of the 17 included studies relevant to massage for back pain. Overall, the authors concluded that massage was effective for persistent back pain, but described the need for further research in the area.

One systematic review included 60 RCTs on complementary and alternative medicine for fibromyalgia pain and found 6 small RCTs relevant to massage. The individual studies varied in whether they favored massage or the control, with most demonstrating no statistical significance. The pooled result reflects this ambivalence, with a nonsignificant positive outcome.

In broad review of massage for musculoskeletal pain, 26 studies contributed to findings supporting the use of massage for shoulder pain and osteoarthritis of the knee, while no benefits or reductions in pain were found for low back pain, neck pain, fibromyalgia, and general musculoskeletal pain. These studies had different follow-up periods and comparators, contributing to the very low strength and heterogeneous nature of the evidence from this systematic review. The other systematic review with very low strength of evidence for mixed results examined the use of complementary and alternative medicine for cancer pain in 14 studies, 4 of which included massage. The studies were split between showing no difference and improvements in pain with massage, with the small sample sizes and other methodological considerations creating additional uncertainty.

Seven high-quality systematic reviews found very low strength of evidence demonstrating unclear findings for massage.^15,33,45-48,53^ These reviews all described the need for more research before any conclusions could be drawn for topics including tendinitis, labor, neck pain, headache, and other musculoskeletal conditions.

### Findings from Low Quality Systematic Reviews

Ten systematic reviews were scored as having not met 3 or more quality criteria using AMSTAR. This indicates that there were flaws in the reporting or methodology of these systematic reviews that make it difficult to determine how their findings should be interpreted. As such, these findings were not able to be categorized by strength, and the conclusions drawn in these systematic reviews should be interpreted with caution. To the extent that higher quality systematic reviews have covered the same topics, these findings may be interpreted with more confidence than the findings in this group of lower quality reviews. For instance, neck pain, fibromyalgia, low back pain, cancer, and headache have all been the subject of higher quality systematic reviews.

## FEATURES OF MASSAGE DESCRIBED IN INCLUDED SYSTEMATIC REVIEWS

Systematic reviews varied in the amount of detail they collected in describing the massage performed in primary studies, as well as how they reported this information (see Table 2). Twenty of the systematic reviews focused solely on interventions they categorized as massage, while the other 11 systematic reviews included other types of similar interventions in their systematic reviews. This latter group of systematic reviews covered a variety of intervention types, the most common group being types of complementary and alternative medicine.^16,40^ Other examples of interventions included in broad systematic reviews include manual therapies,^34^ exercise,^38^ nonpharmacologic strategies, and conservative treatments,^26^ which included silicone gel application, ultrasound, pressure therapy, hydration, and combinations of therapy in addition to massage.

Table 2 Features of Massage Described in Included Systematic Reviews

Author, year | Focused on massage | Style | Provider | Co-interventions | Duration | Comparators
Anthonissen 2016 | [image] | [image] | [image] | [image] | [image] | [image]
Piper 2016 | [image] | [image] | [image] | [image] | [image] | [image]
Furlan 2015 | [image] | [image] | [image] | [image] | [image] | [image]
Bervoets 2015 | [image] | [image] | [image] | [image] | [image] | [image]
Calixtre 2015 | [image] | [image] | [image] | [image] | [image] | [image]
Keeratitanont 2015 | [image] | [image] | [image] | [image] | [image] | [image]
Yuan 2015 | [image] | [image] | [image] | [image] | [image] | [image]
Loew 2014 | [image] | [image] | [image] | [image] | [image] | [image]
Chaibi 2014 | [image] | [image] | [image] | [image] | [image] | [image]
Cheng 2014 | [image] | [image] | [image] | [image] | [image] | [image]
Li 2014 | [image] | [image] | [image] | [image] | [image] | [image]
Kong 2013 | [image] | [image] | [image] | [image] | [image] | [image]
Patel 2012 | [image] | [image] | [image] | [image] | [image] | [image]
van den Dolder 2014 | [image] | [image] | [image] | [image] | [image] | [image]
Smith 2012 | [image] | [image] | [image] | [image] | [image] | [image]
Terhorst 2011 | [image] | [image] | [image] | [image] | [image] | [image]
Furlan 2010 | [image] | [image] | [image] | [image] | [image] | [image]
Ernst 2009 | [image] | [image] | [image] | [image] | [image] | [image]
Wilkinson 2008 | [image] | [image] | [image] | [image] | [image] | [image]
Ezzo 2007 | [image] | [image] | [image] | [image] | [image] | [image]
Bardia 2006 | [image] | [image] | [image] | [image] | [image] | [image]
Smith 2006 | [image] | [image] | [image] | [image] | [image] | [image]
Haraldsson 2006 | [image] | [image] | [image] | [image] | [image] | [image]
Huntley 2004 | [image] | [image] | [image] | [image] | [image] | [image]
Cherkin 2003 | [image] | [image] | [image] | [image] | [image] | [image]
Simkin 2002 | [image] | [image] | [image] | [image] | [image] | [image]
Pan 2000 | [image] | [image] | [image] | [image] | [image] | [image]
Richards 2000 | [image] | [image] | [image] | [image] | [image] | [image]
Ernst 1999 | [image] | [image] | [image] | [image] | [image] | [image]
Kong 2011 | [image] | [image] | [image] | [image] | [image] | [image]
Lewis 2006 | [image] | [image] | [image] | [image] | [image] | [image]

[image] = yes; [image] = no

All 31 systematic reviews included descriptions of the other interventions against which massage was compared, as well as the duration or timing of massage treatment. Twenty-eight systematic reviews included descriptions of co-interventions, or reported that they excluded studies with co-interventions. These 3 features of massage were most often reported for each primary study included in the review, with variability between these primary studies. Some reviews, like the one by Furlan and colleagues,^16^ parsed out findings for different comparators, while many did not.

Some type of description of massage style was included in all but 2 of the systematic reviews. Two systematic reviews limited included studies to particular types of massage – traditional Thai massage^31^ and deep transverse friction massage^33^ – but these reviews were small, with 6 and 2 included studies respectively. Another 2 systematic reviews included studies of therapeutic massage, however they included a different range of therapies within this categorization, with one including chiropractic management in their review,^52^ while the other explicitly excluded manipulation techniques.^53^ Other systematic reviews had general inclusion criteria for massage interventions, and there was variation in whether related interventions like reflexology or manipulation techniques were included. Some common massage types included Swedish massage, myofascial therapies, Shiatsu, Chinese traditional massage, Thai massage, slow stroke massage, and more general descriptions of massage. As noted in one high-quality systematic review that focused on massage as the sole intervention, most of the primary research studies “lacked a clear definition, description, or rationale for massage, the massage technique, or both.” There is considerable variability both within individual systematic reviews as well as between reviews in what is considered to be massage. Abridged descriptions for each systematic review are provided in the evidence tables (Appendix D).

The feature of massage least often described in the systematic reviews was the provider of the massage therapy. Thirteen systematic reviews did not provide descriptions of the massage provider. Multiple reviews mentioned that primary research study descriptions often did not provide this information, which affected the reviewers' abilities to abstract and report on provider information systematically.

## TYPES OF PAIN IN INCLUDED SYSTEMATIC REVIEWS

Types of pain described by the 31 included systematic reviews are visualized in the word cloud depicted in Figure 3. The size of each pain descriptor is proportional to the number of systematic reviews focused on that pain type, with some reviews covering multiple pain types (eg, neck and low back pain). The most common type of pain included in systematic reviews was neck pain (n=6), with 3 systematic reviews focused exclusively on neck pain, and the others also including low back pain, headache, or shoulder pain. Labor pain and fibromyalgia each had 4 systematic reviews dedicated to that particular pain type, while cancer pain and low back pain each were the subject of 3 systematic reviews. Four pain types were included in 2 systematic reviews: shoulder pain, headache, musculoskeletal pain, and pain treatment in palliation. Tendinitis, temporomandibular disorder, scar pain, back pain, pain in a critical care setting, chronic pain (ie, chronic myofascial pain syndrome, chronic low back pain, and scapulocostal syndrome), and multiple conditions (ie, carpal tunnel syndrome, lateral epicondylitis, subacromial impingement syndrome, and plantar fasciitis) were each the subject of a systematic review. Some of these groupings are overlapping or contain multiple types of pain, and are described in this report as they are described in the original systematic reviews in order to preserve the classifications of the systematic review authors. The 2 reviews of musculoskeletal pain in particular subsumed many of the other pain types, including low back pain, neck pain, and shoulder pain.^29,53^ More detailed descriptions are provided for each review in the evidence tables (Appendix D).

Figure 3 Types of Pain in Included Systematic Reviews

LBP = low back pain; TMJ = temporomandibular disorder