# REFERENCES

1 National Center for Complementary and Integrative Health (NCCIH). Massage Therapy for Health Purposes.
2 American Massage Therapy Association. Types of Massage.
3 National Certification Board for Therapeutic Massage & Bodywork (NCBTMB). Glossary: Therapy and Techniques.
4 Bureau of Labor Statistics, U.S. Department of Labor. (2016). Occupational Outlook Handbook, 2016-17 Edition, Massage Therapists.
5 Field T, Diego M, Solien-Wolfe L. (2014). Massage therapy plus topical analgesic is more effective than massage alone for hand arthritis pain. Journal of bodywork and movement therapies.
6 Ye L, Kalichman L, Spittle A, Dobson F, Bennell K. (2011). Effects of rehabilitative interventions on pain, function and physical impairments in people with hand osteoarthritis: a systematic review. Arthritis research & therapy.
7 Kalichman L. (2010). Massage therapy for fibromyalgia symptoms. Rheumatology international.
8 Kalichman L. (2008). Perineal massage to prevent perineal trauma in childbirth. The Israel Medical Association journal : IMAJ.
9 Shmushkevich Y, Kalichman L. (2013). Myofascial pain in lateral epicondylalgia: A review. Journal of bodywork and movement therapies.
10 Vickers A, Zollman C. (1999). ABC of complementary medicine: Massage therapies. British Medical Journal.
11 American Massage Therapy Association. Uncovering the Hidden Risks in Your Practice.
12 Clarke TC, Black LI, Stussman BJ, Barnes PM, Nahin RL. (2015). Trends in the use of complementary health approaches among adults: United States, 2002–2012. National health statistics reports.
13 American Massage Therapy Association. Industry Fact Sheet.
14 Miake-Lye IM, Hempel S, Shanman R, Shekelle PG. (2016). What is an evidence map? A systematic review of published evidence maps and their definitions, methods, and products. Systematic reviews.
15 Patel KC, Gross A, Graham N, et al. (2012). Massage for mechanical neck disorders. The Cochrane database of systematic reviews.
16 Furlan AD, Yazdi F, Tsertsvadze A, et al. (2010). Complementary and alternative therapies for back pain II. Evidence report/technology assessment.
17 Cherkin DC, Sherman KJ, Deyo RA, Shekelle PG. (2003). A review of the evidence for the effectiveness, safety, and cost of acupuncture, massage therapy, and spinal manipulation for back pain. Annals of internal medicine.
18 Shea BJ, Grimshaw JM, Wells GA, et al. (2007). Development of AMSTAR: a measurement tool to assess the methodological quality of systematic reviews. BMC medical research methodology.
19 Balshem H, Helfand M, Schünemann HJ, et al. (2011). GRADE guidelines: 3. Rating the quality of evidence. Journal of clinical epidemiology.
20 Furlan AD, Imamura M, Dryden T, Irvin E. (2008). Massage for low-back pain. The Cochrane database of systematic reviews.
21 Furlan AD, Brosseau L, Imamura M, Irvin E. (2002). Massage for low back pain. The Cochrane database of systematic reviews.
22 Furlan AD, Yazdi F, Tsertsvadze A, et al. (2012). A systematic review and meta-analysis of efficacy, cost-effectiveness, and safety of selected complementary and alternative medicine for neck and low-back pain. Evidence-based complementary and alternative medicine : eCAM.
23 Furlan AD, Imamura M, Dryden T, Irvin E. (2009). Massage for low back pain: an updated systematic review within the framework of the Cochrane Back Review Group. Spine.
24 Furlan AD, Brosseau L, Imamura M, Irvin E. (2002). Massage for low-back pain: a systematic review within the framework of the Cochrane Collaboration Back Review Group. Spine.
25 Terhorst L, Schneider M. (2012). Complementary and alternative medicine in the treatment of pain in fibromyalgia: A systematic review of randomized controlled trials. BMC complementary and alternative medicine.
26 Anthonissen M, Daly D, Janssens T, Van den Kerckhove E. (2016). The effects of conservative treatments on burn scars: A systematic review. Burns : journal of the International Society for Burn Injuries.
27 Piper S, Shearer HM, Cote P, et al. (2016). The effectiveness of soft-tissue therapy for the management of musculoskeletal disorders and injuries of the upper and lower extremities: A systematic review by the Ontario Protocol for Traffic Injury management (OPTIMa) collaboration. Manual therapy.
28 Furlan AD, Giraldo M, Baskwill A, Irvin E, Imamura M. (2015). Massage for low-back pain. The Cochrane database of systematic reviews.
29 Bervoets DC, Luijsterburg PA, Alessie JJ, Buijs MJ, Verhagen AP. (2015). Massage therapy has short-term benefits for people with common musculoskeletal disorders compared to no treatment: a systematic review. Journal of physiotherapy.
30 Calixtre LB, Moreira RF, Franchini GH, Alburquerque-Sendin F, Oliveira AB. (2015). Manual therapy for the management of pain and limited range of motion in subjects with signs and symptoms of temporomandibular disorder: a systematic review of randomised controlled trials. Journal of oral rehabilitation.
31 Keeratitanont K, Jensen MP, Chatchawan U, Auvichayapat P. (2015). The efficacy of traditional Thai massage for the treatment of chronic pain: A systematic review. Complementary therapies in clinical practice.
32 Yuan SL, Matsutani LA, Marques AP. (2015). Effectiveness of different styles of massage therapy in fibromyalgia: a systematic review and meta-analysis. Manual therapy.
33 Loew LM, Brosseau L, Tugwell P, et al. (2014). Deep transverse friction massage for treating lateral elbow or lateral knee tendinitis. The Cochrane database of systematic reviews.
34 Chaibi A, Russell MB. (2014). Manual therapies for primary chronic headaches: a systematic review of randomized controlled trials. The journal of headache and pain.
35 Cheng YH, Huang GC. (2014). Efficacy of massage therapy on pain and dysfunction in patients with neck pain: a systematic review and meta-analysis.
36 Li YH, Wang FY, Feng CQ, Yang XF, Sun YH. (2014). Massage therapy for fibromyalgia: a systematic review and meta-analysis of randomized controlled trials. PloS one.
37 Kong LJ, Zhan HS, Cheng YW, Yuan WA, Chen B, Fang M. (2013). Massage therapy for neck and shoulder pain: a systematic review and meta-analysis. Evidence-based complementary and alternative medicine : eCAM.
38 van den Dolder PA, Ferreira PH, Refshauge KM. (2014). Effectiveness of soft tissue massage and exercise for the treatment of non-specific shoulder pain: a systematic review with meta-analysis. British journal of sports medicine.
39 Smith CA, Levett KM, Collins CT, Jones L. (2012). Massage, reflexology and other manual methods for pain management in labour. The Cochrane database of systematic reviews.
40 Terhorst L, Schneider MJ, Kim KH, Goozdich LM, Stilley CS. (2011). Complementary and alternative medicine in the treatment of pain in fibromyalgia: a systematic review of randomized controlled trials. Journal of manipulative and physiological therapeutics.
41 Ernst E. (2009). Massage therapy for cancer palliation and supportive care: a systematic review of randomised clinical trials. Supportive care in cancer : official journal of the Multinational Association of Supportive Care in Cancer.
42 Wilkinson S, Barnes K, Storey L. (2008). Massage for symptom relief in patients with cancer: systematic review. Journal of advanced nursing.
43 Ezzo J, Haraldsson BG, Gross AR, et al. (2007). Massage for mechanical neck disorders: a systematic review. Spine.
44 Bardia A, Barton DL, Prokop LJ, Bauer BA, Moynihan TJ. (2006). Efficacy of complementary and alternative medicine therapies in relieving cancer pain: a systematic review. Journal of clinical oncology : official journal of the American Society of Clinical Oncology.
45 Smith CA, Collins CT, Cyna AM, Crowther CA. (2006). Complementary and alternative therapies for pain management in labour. The Cochrane database of systematic reviews.
46 Haraldsson BG, Gross AR, Myers CD, et al. (2006). Massage for mechanical neck disorders. The Cochrane database of systematic reviews.
47 Huntley AL, Coon JT, Ernst E. (2004). Complementary and alternative medicine for labor pain: a systematic review. American journal of obstetrics and gynecology.
48 Simkin PP, O'Hara M. (2002). Nonpharmacologic relief of pain during labor: systematic reviews of 5 methods. American journal of obstetrics and gynecology.
49 Pan CX, Morrison RS, Ness J, Fugh-Berman A, Leipzig RM. (2000). Complementary and alternative medicine in the management of pain, dyspnea, and nausea and vomiting near the end of life. A systematic review. Journal of pain and symptom management.
50 Richards KC, Gibson R, Overton-McCoy AL. (2000). Effects of massage in acute and critical care. AACN clinical issues.
51 Ernst E. (1999). Massage therapy for low back pain: a systematic review. Journal of pain and symptom management.
52 Kong L, Bannuru RR, Yuan W, et al. (2011). Therapeutic massage on pain relief for fibromyalgia: A systematic review and meta-analysis. Arthritis and rheumatism.
53 Lewis M, Johnson MI. (2006). The clinical effectiveness of therapeutic massage for musculoskeletal pain: a systematic review. Physiotherapy.