# METHODS

## TOPIC DEVELOPMENT

This topic was developed in response to a nomination by Stephen Ezeji-Okoye, MD, VA Integrative Health Coordinator, Patient Care Services and Laura Krejci, MSW, Associate Director, Office of Patient Centered Care and Cultural Transformation. The scope was further developed with input from the topic nominators, the ESP Coordinating Center, the review team, and the technical expert panel (TEP).

The scope of this report includes the following:

- An evidence map that provides a visual overview of the distribution of evidence (both what is known and where there is little or no evidence base) for massage therapy for indications of pain; and
- An accompanying narrative that helps stakeholders interpret the state of the evidence to inform policy and clinical decision making.

## SEARCH STRATEGY

The searches for this study consisted of broad searches from database inception through February 17, 2016 using terms related to pain and massage in 3 databases: PubMed, Embase, and Cochrane (see Appendix A for full strategy). Searches were also conducted in the same time range in PubMed related to 3 key publications which identified articles similar to the key publications.^15-17^ We restricted our searches to English language publications.

## STUDY SELECTION

Each title was screened independently by 2 authors for relevance; any article chosen by either reviewer was included in the abstract screen. When citations were ambiguous they were included for further review. Abstracts were then reviewed in duplicate with any discrepancies resolved by a third reviewer. In order to be included, abstracts or titles needed to be relevant to massage, mention pain or a pain-related condition (eg, headache), and discuss a systematic review.

For inclusion in the evidence map, each reference must have represented a unique systematic review that reported pain outcomes for at least one massage intervention. Reports and journal articles from the same study or updates to the same review were included but data were extracted and counted once in these instances. Systematic reviews were still eligible if they covered additional outcomes or other interventions if results for massage for pain were reported separately.

## DATA ABSTRACTION

Each included systematic review had data abstracted by one reviewer and verified by a second reviewer. Abstracted data included: number of studies included in the review that had massage as the intervention and pain as an outcome; total number of studies included in the review; descriptions of the massage style, provider, co-interventions, duration, and comparators; pain type; main findings relevant to massage for pain; and whether the systematic review focused solely on massage as the intervention or included a variety of interventions, of which massage is one.

## QUALITY ASSESSMENT

Each systematic review was assessed using a modified version of the Assessing the Methodological Quality of Systematic Reviews (AMSTAR) criteria.^18^ This 11-item tool was designed to assess the methodological quality of systematic reviews (see full modified tool in Appendix B). Four criteria were relaxed for the quality assessment in this project: (1) the search strategy was not required to have supplemental searches beyond the 2 or more sources being searched; (2) reviews were not required to provide a list of their excluded studies; (3) narrative publication bias discussions were acceptable for systematic reviews not using quantitative methods; and (4) documented sources of support were not required for the included individual studies.

While there is no agreed-upon threshold for AMSTAR criteria above which a systematic review would be considered “high quality,” we used a score of 9 or higher for our purposes. Thus, studies could miss a maximum of 2 criteria and still be considered “high quality.”

## DATA SYNTHESIS

Our evidence mapping process resulted in a visual depiction of the evidence for massage for pain, as well as an accompanying narrative with ancillary figures and tables.

### Evidence Map

The visual depiction uses a bubble plot format to display information on 4 dimensions: bubble size, bubble label, x-axis, and y-axis. This allowed us to provide 4 types of information about each included systematic review, as follows:

Number of articles in systematic review (bubble size): Each systematic review bubble's size is directly proportional to the number of primary research studies included in that systematic review related to the effect of massage for pain.

Pain type (bubble label): Each bubble is labelled with the pain indication(s) discussed by that systematic review.

Effect of massage for pain (x-axis): We grouped systematic reviews into 5 categories of findings they reported on for massage for pain. Reviews that reported massage as more beneficial than the comparator were included in the “potentially better” group, those that reported massage as less beneficial than the comparator were included in the “potentially worse” group, those that suggested insufficient evidence to draw clear conclusions about the effectiveness of massage for pain were included in the “unclear” group, those that had findings that varied within the systematic review were included in the “mixed results” group, and those that were unable to detect differences between massage and the comparator for pain were included in the “no difference” group. Each systematic review had one overall finding included in the bubble plot; if a systematic review had multiple consistent findings it was added to that appropriate group, whereas reviews with multiple conflicting findings were included in the “mixed results” group.

Strength of findings (y-axis): Systematic reviews were grouped into 5 categories based on the strength of their findings, which fall along the y-axis. The first 4 categories came from the GRADE approach,^19^ which takes into account study design limitations, inconsistency, indirectness, and imprecision in primary study results to assess the body of evidence contributing to a particular finding. Findings from systematic reviews that received high quality scores (scores of 9 or higher) were categorized using the GRADE levels. In most cases, these findings were already described with levels of evidence in the original systematic reviews, but in the cases where this was not provided, our group assessed the GRADE score based on the description of findings provided in the systematic review.

Findings from systematic reviews with scores of 8 or lower were not classified using the GRADE criteria, and comprise the fifth and final group along the y-axis: “unable to determine.” The methodological issues with these systematic reviews makes interpretation of the reported findings difficult, as sources of bias may be affecting the results and conclusions drawn.

The findings from high-quality systematic reviews were classified as having one of the following levels for quality of evidence:

- High: We are very confident that the true effect lies close to that of the estimate of the effect. Further research is unlikely to change our confidence in the estimate of effect.
- Moderate: We are moderately confident in the effect estimate. The true effect is likely to be close to the estimate of the effect, but there is a possibility that it is substantially different. Further research is likely to have an important impact on our confidence in the estimate of effect and may change the estimate.
- Low: Our confidence in the effect estimate is limited. The true effect may be substantially different from the estimate of the effect. Further research is very likely to have an important impact on our confidence in the estimate of effect and is likely to change the estimate.
- Very low: We have very little confidence in the effect estimate. The true effect is likely to be substantially different from the estimate of effect. Any estimate of effect is very uncertain.

The evidence map figure also allows the reader to visualize gaps in the literature base, where there is no or little evidence for particular pain indications.

### Narrative Synthesis

The narrative synthesis expands upon the visual evidence map to provide more details from the included systematic reviews. These include descriptions of the findings, the features of massage therapy, and the types of pain.

## TECHNICAL EXPERT PANEL

The technical expert panel (TEP) for the project included: Allison Mitchinson, MPH, Certified Massage Therapist, VA Ann Arbor Healthcare System; Baron Tang, PT, Physical Therapist, Postdoctoral Fellow in Training, Evidence In Motion, White River Junction VA Medical Center; Stephen Ezeji-Okoye, MD, VA Integrative Health Coordinator, Patient Care Services, VA Palo Alto Health Care System; and Laura Krejci, MSW, Associate Director, Office of Patient Centered Care and Cultural Transformation, Department of Veterans Affairs, Washington, DC.

## PEER REVIEW

A draft version of the report was reviewed by technical experts and clinical leadership. Reviewer comments and our response are documented in Appendix C.