# INTRODUCTION

Many Veterans desire complementary and integrative health or alternative medicine modalities, both for treatment and for the promotion of wellness. Given VA's desire to promote evidence-based practice, this evidence mapping project aims to help provide guidance to VA leadership about the distribution of evidence on massage therapy for pain to inform policy and clinical decision making.

The term “massage therapy” encompasses many techniques, and the type varies by a patient's needs and physical conditions.^1^ Common types include Swedish massage, deep tissue massage, sports massage, and chair massage.^2,3^ In general, massage therapists treat patients by using touch to manipulate the muscles and other soft tissues of the body. Massage therapies aim to relieve pain, help heal injuries, improve circulation, relieve stress, increase relaxation, and aid in the general wellness of patients.^4^ Preliminary evidence suggests that massage may help with back pain and may improve the quality of life for people with cancer, depression, or HIV/AIDS.^5-9^ Massage therapy appears to have few risks if used appropriately and provided by a trained massage professional.^10,11^ Results from the 2012 National Health Interview Survey – a national survey conducted on a representative sample of adults in the United States – estimates that approximately 15.4 million adults (6.9%) used massage therapy in the past 12 months.^12^ In the United States, 44 states and the District of Columbia regulate massage therapists or provide voluntary state certification. In states that do not regulate massage therapy, cities, counties, or other local governments also may regulate massage therapists. However, training standards and licensure requirements for massage therapists vary greatly by state and locality.^13^

While massage is thought to be an effective treatment for various types of pain, to date an evidence synthesis surveying the evidence for massage therapy across a broad spectrum of pain types has not been conducted. Given the widespread use of various massage therapies for pain, we conducted an evidence mapping process to determine the distribution of evidence available for various pain indications as well as different forms of massage therapy, identify different gaps in evidence, and inform future research priorities. An evidence map is an overview of a broad research field that describes the volume, nature, and characteristics of research in a particular field.^14^ The objective of this mapping project was to provide a visual overview of the distribution of evidence for massage therapy for indications of pain, as well as an accompanying narrative that will help stakeholders interpret the state of evidence to inform policy and clinical decision-making.