# APPENDIX C PEER REVIEW COMMENTS/AUTHOR RESPONSES

Comment | Response
Pages 4 and 6 Steven Ezeji-Okoye should be Stephen and title should be Integrative Health Coordinator, Patient Care Services. | This has been corrected
A brief discussion of what an “active” or “inactive” comparators would be beneficial. Language is ambiguous in the literature regarding “active” or “inactive” comparators or controls and a discussion of these per study (if at all possible) may help with downstream decision making and may shed greater light on the actual comparative effectiveness of the intervention. | For all findings using the terms “active” or “inactive” we have now added examples or definitions from that particular review to provide more clarity for that finding. Because this report looks at systematic reviews, rather than individual studies, we are limited to reporting what the systematic reviews report, and could not collect these details from the included studies from each of the 31 systematic reviews.
Is it possible to add the date of publication to the evidence map? That would help the reader understand how old the review is. | The dates for each systematic review have been added to the bubble labels in the evidence map.
You might want to comment in your summary that some of these reviews are quite old and could be updated in the future. For example the review on massage in a critical care setting was done in 2000. There are other studies on massage that include patients in a critical care setting that have been published including the largest RCT of massage for postoperative pain which was funded by HSRD and published in 2007(I was a co-investigator on that study. | This has been included in the “Summary and Discussion” section.
I do not understand this sentence on page 14, line 38, “These 3 features of massage were most often reported for each primary studying including in the review, with variability between these primary studies”. | This sentence has been revised to fix the grammatical issues.
My one concern is that when one looks at the Evidence Map and sees “mixed results” for so many of the LBP reviews, it gives a bit of a different picture then when one reads the text. The fact is it seems to me that overall the evidence is fairly good for the utility of massage in LBP and neck pain--and this does come through in the text--but visually when one sees that the bigger reviews of these conditions fall in the “mixed results” category the impression is that the evidence is really equivocal. I realize this may be part of how the evidence map methodology works but for some readers who will only look at the graphic and not read the text I think it is a bit problematic. | Both larger reviews described by the peer reviewer (Furlan, 2010 and Furlan, 2015) are described in the text as finding a number of positive findings, but both also included findings of no difference between massage and the control in certain comparisons. We have updated the evidence map to have these studies crossing the boundary between “mixed results” and “potentially better” in order to signal that both these important systematic reviews do lean positive, with many positive findings.
In most evidence maps that I have reviewed, there is not a bubble representing each review, but rather a bubble representing the strength of evidence for a given condition. This article's representation, which has several bubbles for many conditions, will not be as helpful to decision making (ex: Fibromyalgia has studies in 4 categories). It does represent the wide array of findings, but is not as useful a presentation for the decision makers as a synthesis. | While single bubbles for each condition may be more useful for decision makers, this type of depiction would be less faithful to the evidence, since it would require the report authors to make judgements in synthesizing findings across systematic reviews. The current figure presents the findings of each included systematic review, but does not judge how these would be integrated with each other, which would require looking at all the primary studies within each of the systematic reviews for topics with multiple bubbles. In the example of Fibromyalgia, we would need to see which studies were included in all reviews, and which were included in some but not others to determine a new finding inclusive of all potential evidence. The topics with multiple bubbles, especially with differing findings, may be areas that are ripe for an update systematic review. This is now noted in the “Summary and Discussion” section.