# APPENDIX A SEARCH STRATEGIES

DATABASE SEARCHED & TIME PERIOD COVERED:

PubMed – From inception to 2/17/2016

SEARCH STRATEGY 1:

“Massage”[Mesh] OR massag^*^[tiab] OR massag^*^[ot] OR shiatsu

AND

pain[mh] OR pain^*^[tiab] OR pain^*^[ot] OR pain management[mh] OR ache^*^[tiab] OR sore^*^[tiab] OR discomfort[tiab] OR backache^*^ OR headache^*^

SEARCH STRATEGY 2:

“Similar Article” searches for the following 3 publications:

Patel KC, Gross A, Graham N, Goldsmith CH, Ezzo J, Morien A, Peloso PM, et al. (2012). Massage for mechanical neck disorders. Cochrane Database Syst Rev. .

Furlan AD, Yazdi F, Tsertsvadze A, Gross A, Van Tulder M, Santaguida L, Cherkin D, Gagnier J, Ammendolia C, Ansari MT, Ostermann T, Dryden T, Doucette S, Skidmore B, Daniel R, Tsouros S, Weeks L, Galipeau J. (2010). Complementary and alternative therapies for back pain II. Evid Rep Technol Assess (Full Rep).

Cherkin DC, Sherman KJ, Deyo RA, Shekelle PG. (2003). A review of the evidence for the effectiveness, safety, and cost of acupuncture, massage therapy, and spinal manipulation for back pain. Ann Intern Med.

__________________________________________________________________________________________

DATABASE SEARCHED & TIME PERIOD COVERED:

EMBASE - From inception to 2/17/2016

LANGUAGE:

English

SEARCH STRATEGY:

‘massage’/exp OR ‘massage’ OR massag^*^ OR ‘shiatsu’/exp OR shiatsu

AND

pain^*^ OR ache^*^ OR sore^*^ OR discomfort OR backache^*^ OR headache^*^

NOT

‘case report’/de

AND

Human

__________________________________________________________________________________________

DATABASE SEARCHED & TIME PERIOD COVERED:

Cochrane - From inception to 2/17/2016

massag^*^ or shiatsu:ti,ab,kw (Word variations have been searched)

AND

pain^*^ or ache^*^ or sore^*^ or discomfort or backache^*^ or headache^*^:ti,ab,kw (Word variations have been searched)