# REFERENCES

1 Harris RE, Hebert JR, Wynder EL. Cancer risk in male veterans utilizing the Veterans Administration medical system. Cancer. 1989;64(5):1160-8. [pmid: 2758390].
2 Goffin J, et al. First-line systemic chemotherapy in the treatment of advanced non-small cell lung cancer: a systematic review. Journal of Thoracic Oncology: Official Publication of the International Association for the Study of Lung Cancer. 2010;5(2):260-74. [pmid: 20101151].
3 Zhang X, et al. Maintenance therapy with continuous or switch strategy in advanced non-small cell lung cancer: a systematic review and meta-analysis. Chest. 2011;140(1):117-26. [pmid: 21436247].
4 Balshem H, et al. GRADE guidelines: 3. Rating the quality of evidence. J Clin Epidemiol. 2011;64(4):401-6. [pmid: 21208779].
5 Chemotherapy and supportive care versus supportive care alone for advanced non-small cell lung cancer. Cochrane Database Syst Rev. 2010;(5):CD007309. [pmid: 20464750].
6 Al-Saleh K, Quinton C, Ellis PM. Role of pemetrexed in advanced non-small-cell lung cancer: meta-analysis of randomized controlled trials, with histology subgroup analysis. Curr Oncol. 2012;19(1):e9-e15. [pmid: 22328848].
7 Bosch-Barrera J, Quer N, Brunet J. Costs and ethical issues related to first-line treatment of metastatic non-small-cell lung cancer: considerations from a public healthcare system perspective. Clin Lung Cancer. 2011;12(6):335-40. [pmid: 21816680].
8 Botrel TEA, et al. Efficacy of bevacizumab (Bev) plus chemotherapy (CT) compared to CT alone in previously untreated locally advanced or metastatic non-small cell lung cancer (NSCLC): systematic review and meta-analysis. Lung Cancer. 2011;74(1):89-97. [pmid: 21377753].
9 Bria E, et al. Outcome of advanced NSCLC patients harboring sensitizing EGFR mutations randomized to EGFR tyrosine kinase inhibitors or chemotherapy as first-line treatment: A meta-analysis. Annals of Oncology. 2011;22(10):2277-2285. [pmid: 21325444].
10 Chen P, et al. EGFR-targeted therapies combined with chemotherapy for treating advanced non-small-cell lung cancer: a meta-analysis. European Journal of Clinical Pharmacology. 2011;67(3):235-43. [pmid: 21207017].
11 Fleeman N, et al. Pemetrexed for the first-line treatment of locally advanced or metastatic non-small cell lung cancer. Health Technology Assessment (Winchester, England). Suppl 1. 2010;14:47-53.
12 Gao G, et al. A meta-analysis of paclitaxel-based chemotherapies administered once every week compared with once every 3 weeks first-line treatment of advanced non-small-cell lung cancer. Lung Cancer. 2012.
13 Gao G, et al. Epidermal growth factor receptor-tyrosine kinase inhibitor therapy is effective as first-line treatment of advanced non-small-cell lung cancer with mutated EGFR: A meta-analysis from six phase III randomized controlled trials. International Journal of Cancer. 2012.
14 Ibrahim EM. Frontline gefitinib in advanced non-small cell lung cancer: Meta-analysis of published randomized trials. Annals of Thoracic Medicine. 2010;5(3):153-60. [pmid: 20835310].
15 Ibrahim EM, et al. Cetuximab-based therapy is effective in chemotherapy-naive patients with advanced and metastatic non-small-cell lung cancer: a meta-analysis of randomized controlled trials. Lung. 2011;189(3):193-8. [pmid: 21424607].
16 Ku GY, Haaland BA, de Lima Lopes G Jr. Gefitinib vs. chemotherapy as first-line therapy in advanced non-small cell lung cancer: meta-analysis of phase III trials. Lung Cancer. 2011;74(3):469-73. [pmid: 21565418].
17 Li C, et al. Gemcitabine plus paclitaxel versus carboplatin plus either gemcitabine or paclitaxel in advanced non-small-cell lung cancer: a literature-based meta-analysis. Lung. 2010;188(5):359-64. [pmid: 20703493].
18 Liang HY, et al. Chemo-radiotherapy for advanced non-small cell lung cancer: concurrent or sequential? It’s no longer the question: a systematic review. Int J Cancer. 2010;127(3):718-28. [pmid: 19957329].
19 Lin H, et al. Chemotherapy with cetuximab or chemotherapy alone for untreated advanced non-small-cell lung cancer: a systematic review and meta-analysis. Lung Cancer. 2010;70(1):57-62. [pmid: 20149474].
20 Mountzios G, Syrigos KN. A benefit-risk assessment of erlotinib in non-small-cell lung cancer and pancreatic cancer. Drug Safety. 2011;34(3):175-86. [pmid: 21332242].
21 Petrelli F, et al. Efficacy of EGFR tyrosine kinase inhibitors in patients with EGFR-mutated non-small-cell lung cancer: a meta-analysis of 13 randomized trials. Clinical Lung Cancer. 2012;13(2):107-14. [pmid: 22056888].
22 Wang F, et al. Gefitinib Compared with Systemic Chemotherapy as First-line Treatment for Chemotherapy-naive Patients with Advanced Non-small Cell Lung Cancer: A Meta-analysis of Randomised Controlled Trials. Clinical Oncology. 2011.
23 Yu Y, et al. Nonplatinum regimens of gemcitabine plus docetaxel versus platinum-based regimens in first-line treatment of advanced non-small cell lung cancer: a meta-analysis on 9 randomized controlled trials. Cancer Chemotherapy and Pharmacology. 2012:1-11.
24 Azim HA Jr, et al. Third generation triplet cytotoxic chemotherapy in advanced non-small cell lung cancer: a systematic overview. Lung Cancer. 2009;64(2):194-8. [pmid: 18809226].
25 Kosmidis PA, et al. Paclitaxel and gemcitabine versus paclitaxel and vinorelbine in patients with advanced non-small-cell lung cancer. A phase III study of the Hellenic Cooperative Oncology Group (HeCOG). Annals of Oncology. 2011;22(4):827-34. [pmid: 20880999].
26 Shea BJ, et al. Development of AMSTAR: a measurement tool to assess the methodological quality of systematic reviews. BMC Med Res Methodol. 2007;7:10. [pmid: 17302989].
27 Baggstrom MQ, et al. Third-generation chemotherapy agents in the treatment of advanced non-small cell lung cancer: a meta-analysis. Journal of Thoracic Oncology: Official Publication of the International Association for the Study of Lung Cancer. 2007;2(9):845-53. [pmid: 17805063].
28 Belani CP, et al. Randomized phase III trial comparing cisplatin-etoposide to carboplatin-paclitaxel in advanced or metastatic non-small cell lung cancer. Ann Oncol. 2005;16(7):1069-75. [pmid: 15860487].
29 Ichinose Y, et al. A multicenter randomized phase III trial of docetaxel + cisplatin (DP) vs. vindesine + cisplatin (VP) in patients with untreated stage IV non-small cell lung cancer (NSCLC) (abstract). Ann Oncol. 2002;13(suppl 5):132-133.
30 Kim JH, et al. Randomized phase II study of gemcitabine plus cisplatin versus etoposide plus cisplatin for the treatment of locally advanced or metastatic non-small cell lung cancer: Korean Cancer Study Group experience. Lung Cancer. 2006;52(1):75-81. [pmid: 16488054].
31 Park HS, et al. Randomized trial of docetaxel plus cisplatin (DC) versus etoposide plus cisplatin (EC) in locally advanced, recurrent, or metastatic non-small cell lung cancer (NSCLC) (abstract). European Journal of Cancer. 2003;1:S240.
32 Takiguchi Y, et al. The final results of a randomized phase III trial comparing irinotecan (CPT-11) and cisplatin (CDDP) with vindesine (VDS) and CDDP in advanced non-small cell lung cancer (NSCLC). Lung Cancer. 2000;29(Suppl 1):28-29.
33 Schmittel A, et al. A German multicenter, randomized phase III trial comparing irinotecan-carboplatin with etoposide-carboplatin as first-line therapy for extensive-disease small-cell lung cancer. Annals of Oncology. 2011;22(8):1798-804. [pmid: 21266516].
34 Zatloukal P, et al. A multicenter international randomized phase III study comparing cisplatin in combination with irinotecan or etoposide in previously untreated small-cell lung cancer patients with extensive disease. Annals of Oncology. 2010;21(9):1810-6. [pmid: 20231298].
35 Yamamoto N, et al. Phase III study comparing second- and third-generation regimens with concurrent thoracic radiotherapy in patients with unresectable stage III non-small-cell lung cancer: West Japan Thoracic Oncology Group WJTOG0105. Journal of Clinical Oncology. 2010;28(23):3739-45. [pmid: 20625120].
36 Socinski MA, et al. Phase III study of pemetrexed plus carboplatin compared with etoposide plus carboplatin in chemotherapy-naive patients with extensive-stage small-cell lung cancer. Journal of Clinical Oncology. 2009;27(28):4787-92. [pmid: 19720897].
37 Lee SM, et al. Comparison of gemcitabine and carboplatin versus cisplatin and etoposide for patients with poor-prognosis small cell lung cancer. Thorax. 2009;64(1):75-80. [pmid: 18786981].
38 Dimitroulis J, et al. Comparison of cisplatin-paclitaxel combination versus cisplatin-etoposide in patients with small-cell lung cancer: a Phase III study. Oncology Reports. 2008;20(4):879-84. [pmid: 18813830].
39 Hermes A, et al. Irinotecan plus carboplatin versus oral etoposide plus carboplatin in extensive small-cell lung cancer: a randomized phase III trial. Journal of Clinical Oncology. 2008;26(26):4261-7. [pmid: 18779613].
40 Hotta K, et al. Addition of platinum compounds to a new agent in patients with advanced non-small-cell lung cancer: a literature based meta-analysis of randomised trials. Ann Oncol. 2004;15(12):1782-9. [pmid: 15550583].
41 Reynolds C, et al. Randomized phase III trial of gemcitabine-based chemotherapy with in situ RRM1 and ERCC1 protein levels for response prediction in non-small-cell lung cancer. Journal of Clinical Oncology. 2009;27(34):5808-15. [pmid: 19884554].
42 Lilenbaum R, et al. A randomized phase III trial of single-agent pemetrexed (P) versus carboplatin and pemetrexed (CP) in patients with advanced non-small cell lung cancer (NSCLC) and performance status (PS) of 2. J Clin Oncol. 2012;30(suppl 2012 ASCO Annual Meeting abstracts):abstr 7506.
43 Le Chevalier T, et al. Efficacy of gemcitabine plus platinum chemotherapy compared with other platinum containing regimens in advanced non-small-cell lung cancer: a meta-analysis of survival outcomes. Lung Cancer. 2005;47(1):69-80. [pmid: 15603856].
44 Douillard JY, et al. Comparison of docetaxel- and vinca alkaloid-based chemotherapy in the first-line treatment of advanced non-small cell lung cancer: a meta-analysis of seven randomized clinical trials. J Thorac Oncol. 2007;2(10):939-46. [pmid: 17909357].
45 Schiller JH, et al. Comparison of four chemotherapy regimens for advanced non-small-cell lung cancer. N Engl J Med. 2002;346(2):92-8. [pmid: 11784875].
46 Scagliotti GV, et al. Phase III randomized trial comparing three platinum-based doublets in advanced non-small-cell lung cancer. J Clin Oncol. 2002;20(21):4285-91. [pmid: 12409326].
47 Rubio JE, Shahagun G. A randomized phase III trial comparing docetaxel + carboplatin (DCP) vs vinorelbine + carboplatin (VCP) in non small cell lung cancer (NSCLC) stage III and IV (abstract). Proc Am Soc Clin Oncol. 2003;22:703.
48 Martoni A, et al. Multicentre randomised phase III study comparing the same dose and schedule of cisplatin plus the same schedule of vinorelbine or gemcitabine in advanced non-small cell lung cancer. Eur J Cancer. 2005;41(1):81-92. [pmid: 15617993].
49 Gebbia V, et al. Gemcitabine and cisplatin versus vinorelbine and cisplatin versus ifosfamide+gemcitabine followed by vinorelbine and cisplatin versus vinorelbine and cisplatin followed by ifosfamide and gemcitabine in stage IIIB-IV non small cell lung carcinoma: a prospective randomized phase III trial of the Gruppo Oncologico Italia Meridionale. Lung Cancer. 2003;39(2):179-89. [pmid: 12581571].
50 Fossella F, et al. Randomized, multinational, phase III study of docetaxel plus platinum combinations versus vinorelbine plus cisplatin for advanced non-small-cell lung cancer: the TAX 326 study group. J Clin Oncol. 2003;21(16):3016-24. [pmid: 12837811].
51 Ohe Y, et al. Randomized phase III study of cisplatin plus irinotecan versus carboplatin plus paclitaxel, cisplatin plus gemcitabine, and cisplatin plus vinorelbine for advanced non-small-cell lung cancer: Four-Arm Cooperative Study in Japan. Annals of Oncology. 2007;18(2):317-23. [pmid: 17079694].
52 Helbekkmo N, et al. Vinorelbine/carboplatin vs gemcitabine/carboplatin in advanced NSCLC shows similar efficacy, but different impact of toxicity. British Journal of Cancer. 2007;97(3):283-9. [pmid: 17595658].
53 Chang J.W.-C, et al. A randomized study of gemcitabine plus cisplatin and vinorelbine plus cisplatin in patients with advanced non-small-cell lung cancer. Chang Gung Medical Journal. 2008;31(6):559-66. [pmid: 19241895].
54 Gronberg BH, et al. Phase III study by the Norwegian lung cancer study group: pemetrexed plus carboplatin compared with gemcitabine plus carboplatin as first-line chemotherapy in advanced non-small-cell lung cancer. Journal of Clinical Oncology. 2009;27(19):3217-24. [pmid: 19433683].
55 Okamoto I, et al. Phase III trial comparing oral S-1 plus carboplatin with paclitaxel plus carboplatin in chemotherapy-naive patients with advanced non-small-cell lung cancer: results of a west Japan oncology group study. Journal of Clinical Oncology. 2010;28(36):5240-6. [pmid: 21079147].
56 Rodrigues-Pereira J, et al. A randomized phase 3 trial comparing pemetrexed/carboplatin and docetaxel/carboplatin as first-line treatment for advanced, nonsquamous non-small cell lung cancer. Journal of Thoracic Oncology: Official Publication of the International Association for the Study of Lung Cancer. 2011;6(11):1907-14. [pmid: 22005471].
57 Scagliotti GV, et al. Phase III study comparing cisplatin plus gemcitabine with cisplatin plus pemetrexed in chemotherapy-naive patients with advanced-stage non-small-cell lung cancer. Journal of Clinical Oncology. 2008;26(21):3543-51. [pmid: 18506025].
58 Tan EH, et al. Global Lung Oncology Branch trial 3 (GLOB3): final results of a randomised multinational phase III study alternating oral and i.v. vinorelbine plus cisplatin versus docetaxel plus cisplatin as first-line treatment of advanced non-small-cell lung cancer. Annals of Oncology. 2009;20(7):1249-56. [pmid: 19276396].
59 Treat JA, et al. A randomized, phase III multicenter trial of gemcitabine in combination with carboplatin or paclitaxel versus paclitaxel plus carboplatin in patients with advanced or metastatic non-small-cell lung cancer. Annals of Oncology. 2010;21(3):540-7. [pmid: 19833819].
60 Weissman CH, et al. A phase III randomized trial of gemcitabine-oxaliplatin versus carboplatin-paclitaxel as first-line therapy in patients with advanced non-small cell lung cancer. Journal of Thoracic Oncology: Official Publication of the International Association for the Study of Lung Cancer. 2011;6(2):358-64. [pmid: 21206386].
61 Langer CJ, et al. Phase III trial comparing paclitaxel poliglumex (CT-2103, PPX) in combination with carboplatin versus standard paclitaxel and carboplatin in the treatment of PS 2 patients with chemotherapy-naive advanced non-small cell lung cancer. Journal of Thoracic Oncology: Official Publication of the International Association for the Study of Lung Cancer. 2008;3(6):623-30. [pmid: 18520802].
62 Blanchard EM, et al. Comparison of platinum-based chemotherapy in patients older and younger than 70 years: an analysis of Southwest Oncology Group Trials 9308 and 9509. Journal of Thoracic Oncology: Official Publication of the International Association for the Study of Lung Cancer. 2011;6(1):115-20. [pmid: 21107287].
63 Treat J, et al. Comparison of pemetrexed plus cisplatin with other first-line doublets in advanced non-small cell lung cancer (NSCLC): A combined analysis of three phase 3 trials. Lung Cancer. 2012;76(2):222-7. [pmid: 22115704].
64 Kelly K, et al. Randomized phase III trial of paclitaxel plus carboplatin versus vinorelbine plus cisplatin in the treatment of patients with advanced non--small-cell lung cancer: a Southwest Oncology Group trial. J Clin Oncol. 2001;19(13):3210-8. [pmid: 11432888].
65 D’Addario G, et al. Platinum-based versus nonplatinum-based chemotherapy in advanced non-small-cell lung cancer: a meta-analysis of the published literature. J Clin Oncol. 2005;23(13):2926-36. [pmid: 15728229].
66 Kawahara M, et al. Phase III randomized study of vinorelbine (V), gemcitabine (G) followed by docetaxel (D) (VDG) versus paclitaxel (P) and carboplatin (C) (PC) in patients (pts) with advanced non-small cell lung cancer (NSCLC) (Japan Multinational Trial Organization LC00-03) [abstract]. Proc Am Soc Clin Oncol. 2006;24:367s.
67 Pujol JL, Barlesi F, Daures JP. Should chemotherapy combinations for advanced non-small cell lung cancer be platinum-based? A meta-analysis of phase III randomized trials. Lung Cancer. 2006;51(3):335-45. [pmid: 16478643].
68 Rigas J, Dragnev K, Kerry M. Survival equivalence of nonplatinum-based and latinum-based chemotherapy for advanced non-small-cell lung cancer (NSCLC): the results of a multicenter internet-based phase III randomized study (D0112) (abstract). Lung Cancer. 2005;49:S35.
69 Tan EH, et al. Randomized study of vinorelbine--gemcitabine versus vinorelbine--carboplatin in patients with advanced non-small cell lung cancer. Lung Cancer. 2005;49(2):233-40. [pmid: 16022917].
70 Treat J. A randomized phase III trial of gemcitabine (G) in combination with carboplatin (C) or paclitaxel (P) versus paclitaxel plus carboplatin in advanced (stage IIIB, IV) non-small cell lung cancer (NSCLC) (abstract). Proc Am Soc Clin Oncol. 2003;21:624.
71 Hsu C, et al. Gemcitabine plus conventional-dose epirubicin versus gemcitabine plus cisplatin as first-line chemotherapy for stage IIIB/IV non-small cell lung carcinoma--a randomized phase II trial. Lung Cancer. 2008;62(3):334-43. [pmid: 18450322].
72 Kosmidis PA, et al. Paclitaxel and gemcitabine versus carboplatin and gemcitabine in patients with advanced non-small-cell lung cancer. A phase III study of the Hellenic Cooperative Oncology Group. Annals of Oncology. 2008;19(1):115-22. [pmid: 17938425].
73 Ardizzoni A, et al. Cisplatin- versus carboplatin-based chemotherapy in first-line treatment of advanced non-small-cell lung cancer: an individual patient data meta-analysis. J Natl Cancer Inst. 2007;99:847-857. [pmid: 17551145].
74 Hotta K, et al. Meta-analysis of randomized clinical trials comparing Cisplatin to Carboplatin in patients with advanced non-small-cell lung cancer. J Clin Oncol. 2004;22(19):3852-9. [pmid: 15326195].
75 Jiang J, et al. A meta-analysis of randomized controlled trials comparing carboplatin-based to cisplatin-based chemotherapy in advanced non-small cell lung cancer. Lung Cancer. 2007;57(3):348-58. [pmid: 17485133].
76 Socinski MA, et al. Treatment of non-small cell lung cancer, stage IV: ACCP evidence-based clinical practice guidelines (2nd edition). Chest. 2007;132(3 Suppl):277S-289S. [pmid: 17873174].
77 Alberola V, et al. Cisplatin plus gemcitabine versus a cisplatin-based triplet versus nonplatinum sequential doublets in advanced non-small-cell lung cancer: a Spanish Lung Cancer Group phase III randomized trial. J Clin Oncol. 2003;21(17):3207-13. [pmid: 12947054].
78 Booton R, et al. A phase III trial of docetaxel/carboplatin versus mitomycin C/ifosfamide/cisplatin (MIC) or mitomycin C/vinblastine/cisplatin (MVP) in patients with advanced non-small-cell lung cancer: a randomised multicentre trial of the British Thoracic Oncology Group (BTOG1). Ann Oncol. 2006;17(7):1111-9. [pmid: 16603599].
79 Laack E, et al. Randomized phase III study of gemcitabine and vinorelbine versus gemcitabine, vinorelbine, and cisplatin in the treatment of advanced non-small-cell lung cancer: from the German and Swiss Lung Cancer Study Group. J Clin Oncol. 2004;22(12):2348-56. [pmid: 15197195].
80 Melo M, et al. Results of a randomized phase III trial comparing 4 cisplatin (P)-based regimens in the treatment of locally advanced and metastatic non-small cell lung cancer (NSCLC):mitomycin/vinblastine/cisplatin (MVP) is no longer a therapeutic option (abstract). Proc Am Soc Clin Oncol. 2002;21:302a.
81 Sculier JP, et al. A three-arm phase III randomised trial comparing combinations of platinum derivatives, ifosfamide and/or gemcitabine in stage IV non-small-cell lung cancer. Ann Oncol. 2002;13(6):874-82. [pmid: 12123332].
82 Souquet PJ, et al. GLOB-1: a prospective randomised clinical phase III trial comparing vinorelbine-cisplatin with vinorelbine-ifosfamide-cisplatin in metastatic non-small-cell lung cancer patients. Ann Oncol. 2002;13(12):1853-61. [pmid: 12453852].
83 Boni C, et al. Triplets versus doublets, with or without cisplatin, in the first-line treatment of stage IIIB-IV non-small cell lung cancer (NSCLC) patients: a multicenter randomised factorial trial (FAST). British Journal of Cancer. 2012;106(4):658-65. [pmid: 22240782].
84 Comella P, et al. Efficacy of the combination of cisplatin with either gemcitabine and vinorelbine or gemcitabine and paclitaxel in the treatment of locally advanced or metastatic non-small-cell lung cancer: a phase III randomised trial of the Southern Italy Cooperative Oncology Group (SICOG 0101). Annals of Oncology. 2007;18(2):324-30. [pmid: 17071935].
85 Greco FA, et al. Paclitaxel/Carboplatin/gemcitabine versus gemcitabine/vinorelbine in advanced non-small-cell lung cancer: a phase II/III study of the Minnie Pearl Cancer Research Network. Clinical Lung Cancer. 2007;8(8):483-7. [pmid: 17922972].
86 Kubota K, et al. Vinorelbine plus gemcitabine followed by docetaxel versus carboplatin plus paclitaxel in patients with advanced non-small-cell lung cancer: a randomised, open-label, phase III study. Lancet Oncology. 2008;9(12):1135-42. [pmid: 19013107].
87 Blumenschein GR Jr, et al. Phase III trial comparing carboplatin, paclitaxel, and bexarotene with carboplatin and paclitaxel in chemotherapy-naive patients with advanced or metastatic non-small-cell lung cancer: SPIRIT II. Journal of Clinical Oncology. 2008;26(11):1879-85. [pmid: 18398153].
88 Goss GD, et al. Randomized, double-blind trial of carboplatin and paclitaxel with either daily oral cediranib or placebo in advanced non-small-cell lung cancer: NCIC clinical trials group BR24 study. Journal of Clinical Oncology. 2010;28(1):49-55. [pmid: 19917841].
89 Han B, et al. A multicenter, randomized, double-blind, placebo-controlled study to evaluate the efficacy of paclitaxel-carboplatin alone or with endostar for advanced non-small cell lung cancer. Journal of Thoracic Oncology: Official Publication of the International Association for the Study of Lung Cancer. 2011;6(6):1104-9. [pmid: 21532504].
90 Hirsh V, et al. Randomized phase III trial of paclitaxel/carboplatin with or without PF-3512676 (Toll-like receptor 9 agonist) as first-line treatment for advanced non-small-cell lung cancer. Journal of Clinical Oncology. 2011;29(19):2667-74. [pmid: 21632509].
91 Lynch TJ, et al. Cetuximab and first-line taxane/carboplatin chemotherapy in advanced non-small-cell lung cancer: results of the randomized multicenter phase III trial BMS099. Journal of Clinical Oncology. 2010;28(6):911-7. [pmid: 20100966].
92 Manegold C, et al. A phase III randomized study of gemcitabine and cisplatin with or without PF-3512676 (TLR9 agonist) as first-line treatment of advanced non-small-cell lung cancer. Annals of Oncology. 2012;23(1):72-7. [pmid: 21464154].
93 Mok TSK, et al. Efficacy of bevacizumab with cisplatin and gemcitabine in Asian patients with advanced or recurrent non-squamous non-small cell lung cancer who have not received prior chemotherapy: a substudy of the Avastin in Lung trial. [Erratum appears in Asia Pac J Clin Oncol. 2011 Sep;7(3):321 Note: Thitiya, Sirisinha [corrected to Sirisinha, Thitiya]]. Asia-Pacific Journal of Clinical Oncology. Suppl 2. 2011;7:4-12. [pmid: 21585703].
94 Ramlau R, et al. Randomized phase III trial comparing bexarotene (L1069-49)/cisplatin/vinorelbine with cisplatin/vinorelbine in chemotherapy-naive patients with advanced or metastatic non-small-cell lung cancer: SPIRIT I. Journal of Clinical Oncology. 2008;26(11):1886-92. [pmid: 18398154].
95 Reck M, et al. Overall survival with cisplatin-gemcitabine and bevacizumab or placebo as first-line therapy for nonsquamous non-small-cell lung cancer: results from a randomised phase III trial (AVAiL). Annals of Oncology. 2010;21(9):1804-9. [pmid: 20150572].
96 Scagliotti G, et al. Phase III study of carboplatin and paclitaxel alone or with sorafenib in advanced non-small-cell lung cancer. Journal of Clinical Oncology. 2010;28(11):1835-42. [pmid: 20212250].
97 Gatzemeier U, et al. Phase III study of erlotinib in combination with cisplatin and gemcitabine in advanced non-small-cell lung cancer: the Tarceva Lung Cancer Investigation Trial. Journal of Clinical Oncology. 2007;25(12):1545-52. [pmid: 17442998].
98 Giaccone G, et al. Gefitinib in combination with gemcitabine and cisplatin in advanced non-small-cell lung cancer: a phase III trial--INTACT 1. J Clin Oncol. 2004;22(5):777-84. [pmid: 14990632].
99 Herbst RS, et al. TRIBUTE: a phase III trial of erlotinib hydrochloride (OSI-774) combined with carboplatin and paclitaxel chemotherapy in advanced non-small-cell lung cancer. J Clin Oncol. 2005;23(25):5892-9. [pmid: 16043829].
100 Herbst RS, et al. Gefitinib in combination with paclitaxel and carboplatin in advanced non-small-cell lung cancer: a phase III trial--INTACT 2. J Clin Oncol. 2004;22(5):785-94. [pmid: 14990633].
101 Sandler A, et al. Paclitaxel-carboplatin alone or with bevacizumab for non-small-cell lung cancer. N Engl J Med. 2006;355(24):2542-50. [pmid: 17167137].
102 Reck M, et al. Phase III trial of cisplatin plus gemcitabine with either placebo or bevacizumab as first-line therapy for nonsquamous non-small-cell lung cancer: AVAil. Journal of clinical oncology : official journal of the American Society of Clinical Oncology. 2009:1227-34. [pmid: 19188680].
103 Paz-Ares L, et al. Phase III study of gemcitabine and cisplatin with or without aprinocarsen, a protein kinase C-alpha antisense oligonucleotide, in patients with advanced-stage non-small-cell lung cancer. J Clin Oncol. 2006;24(9):1428-34. [pmid: 16549837].
104 Pirker R, et al. Cetuximab plus chemotherapy in patients with advanced non-small-cell lung cancer (FLEX): an open-label randomised phase III trial. Lancet. 2009;373(9674):1525-31. [pmid: 19410716].
105 Gaafar RM, et al. A double-blind, randomised, placebo-controlled phase III intergroup study of gefitinib in patients with advanced NSCLC, non-progressing after first line platinum-based chemotherapy (EORTC 08021/ILCP 01/03). European Journal of Cancer. 2011;47(15):2331-40. [pmid: 21802939].
106 Takeda K, et al. Randomized phase III trial of platinum-doublet chemotherapy followed by gefitinib compared with continued platinum-doublet chemotherapy in Japanese patients with advanced non-small-cell lung cancer: results of a west Japan thoracic oncology group trial (WJTOG0203). Journal of Clinical Oncology. 2010;28(5):753-60. [pmid: 20038730].
107 Thongprasert S, et al. Health-related quality-of-life in a randomized phase III first-line study of gefitinib versus carboplatin/paclitaxel in clinically selected patients from Asia with advanced NSCLC (IPASS). Journal of Thoracic Oncology: Official Publication of the International Association for the Study of Lung Cancer. 2011;6(11):1872-80. [pmid: 22011650].
108 Mok TS, et al. Gefitinib or carboplatin-paclitaxel in pulmonary adenocarcinoma. New England Journal of Medicine. 2009;361(10):947-57. [pmid: 19692680].
109 Maemondo M, et al. Gefitinib or chemotherapy for non-small-cell lung cancer with mutated EGFR. New England Journal of Medicine. 2010;362(25):2380-8. [pmid: 20573926].
110 Mitsudomi T, et al. Gefitinib versus cisplatin plus docetaxel in patients with nonsmall- cell lung cancer harbouring mutations of the epidermal growth factor receptor (WJTOG3405): an open label, randomised phase 3 trial. Lancet Oncology. 2010;11(2):121-8. [pmid: 20022809].
111 Han JY, et al. First-SIGNAL: first-line single-agent iressa versus gemcitabine and cisplatin trial in never-smokers with adenocarcinoma of the lung. J Clin Oncol. 2012;30(10):1122-8. [pmid: 22370314].
112 Zhou C, et al. Erlotinib versus chemotherapy as first-line treatment for patients with advanced EGFR mutation-positive non-small-cell lung cancer (OPTIMAL, CTONG-0802): a multicentre, open-label, randomised, phase 3 study. Lancet Oncology. 2011;12(8):735-42. [pmid: 21783417].
113 Rosell R, et al. Erlotinib versus standard chemotherapy as first-line treatment for European patients with advanced EGFR mutation-positive non-small-cell lung cancer (EURTAC): a multicentre, open-label, randomised phase 3 trial. Lancet Oncology. 2012;13(3):239-46. [pmid: 22285168].
114 Gridelli C, et al. First-Line Erlotinib Followed by Second-Line Cisplatin-Gemcitabine Chemotherapy in Advanced Non-Small-Cell Lung Cancer: The TORCH Randomized Trial. J Clin Oncol. 2012;30(24):3002-11. [pmid: 22778317].
115 Quoix E, et al. Carboplatin and weekly paclitaxel doublet chemotherapy compared with monotherapy in elderly patients with advanced non-small-cell lung cancer: IFCT-0501 randomised, phase 3 trial. Lancet. 2011;378(9796):1079-88. [pmid: 21831418].
116 Hainsworth JD, et al. Weekly docetaxel versus docetaxel/gemcitabine in the treatment of elderly or poor performance status patients with advanced nonsmall cell lung cancer: a randomized phase 3 trial of the Minnie Pearl Cancer Research Network. Cancer. 2007;110(9):2027-34. [pmid: 17823908].
117 Georgoulias V, et al. Docetaxel versus docetaxel plus gemcitabine as front-line treatment of patients with advanced non-small cell lung cancer: a randomized, multicenter phase III trial. Lung Cancer. 2008;59(1):57-63. [pmid: 17765354].
118 Comella P, et al. Gemcitabine with either paclitaxel or vinorelbine vs paclitaxel or gemcitabine alone for elderly or unfit advanced non-small-cell lung cancer patients. Br J Cancer. 2004;91(3):489-97. [pmid: 15266334].
119 Gridelli C, et al. Chemotherapy for elderly patients with advanced non-small-cell lung cancer: the Multicenter Italian Lung Cancer in the Elderly Study (MILES) phase III randomized trial. J Natl Cancer Inst. 2003;95(5):362-72. [pmid: 12618501].
120 Kudoh S, et al. Phase III study of docetaxel compared with vinorelbine in elderly patients with advanced non-small-cell lung cancer: results of the West Japan Thoracic Oncology Group Trial (WJTOG 9904). J Clin Oncol. 2006;24(22):3657-63. [pmid: 16877734].
121 Georgoulias V, et al. Vinorelbine plus cisplatin versus docetaxel plus gemcitabine in advanced non-small-cell lung cancer: a phase III randomized trial. J Clin Oncol. 2005;23(13):2937-45. [pmid: 15728228].
122 Kosmidis P, et al. Paclitaxel plus carboplatin versus gemcitabine plus paclitaxel in advanced non-small-cell lung cancer: a phase III randomized trial. J Clin Oncol. 2002;20(17):3578-85. [pmid: 12202657].
123 Shepherd FA, et al. Prospective randomized trial of docetaxel versus best supportive care in patients with non-small-cell lung cancer previously treated with platinum-based chemotherapy. J Clin Oncol. 2000;18(10):2095-103. [pmid: 10811675].
124 Qi WX, et al. Effectiveness and safety of pemetrexed-based doublet versus pemetrexed alone as second-line treatment for advanced non-small-cell lung cancer: a systematic review and meta-analysis. J Cancer Res Clin Oncol. 2012.
125 Qi W.-X, et al. The role of vandetanib in the second-line treatment for advanced non-small-cell-lung cancer: a meta-analysis of four randomized controlled trials. Lung. 2011;189(6):437-43. [pmid: 21986852].
126 Qi W.-X, Shen Z, Yao Y. Meta-analysis of docetaxel-based doublet versus docetaxel alone as second-line treatment for advanced non-small-cell lung cancer. Cancer Chemotherapy & Pharmacology. 2012;69(1):99-106. [pmid: 21607554].
127 Yang K, et al. Effectiveness and safety of bevacizumab for unresectable non-small-cell lung cancer: a meta-analysis. Clinical Drug Investigation. 2010;30(4):229-41. [pmid: 20225906].
128 Herbst RS, et al. Phase II study of efficacy and safety of bevacizumab in combination with chemotherapy or erlotinib compared with chemotherapy alone for treatment of recurrent or refractory non small-cell lung cancer. J Clin Oncol. 2007;25(30):4743-50. [pmid: 17909199].
129 Johnson DH, et al. Randomized phase II trial comparing bevacizumab plus carboplatin and paclitaxel with carboplatin and paclitaxel alone in previously untreated locally advanced or metastatic non-small-cell lung cancer. J Clin Oncol. 2004;22(11):2184-91. [pmid: 15169807].
130 Shepherd FA, et al. Erlotinib in previously treated non-small-cell lung cancer. N Engl J Med. 2005;353(2):123-32. [pmid: 16014882].
131 Di Maio M, et al. Individual patient data meta-analysis of docetaxel administered once every 3 weeks compared with once every week second-line treatment of advanced non-small- cell lung cancer. Journal of Clinical Oncology. 2007;25(11):1377-82. [pmid: 17416857].
132 Di Maio M, et al. Meta-analysis of single-agent chemotherapy compared with combination chemotherapy as second-line treatment of advanced non-small-cell lung cancer. J Clin Oncol. 2009;27(11):1836-43. [pmid: 19273711].
133 Gebbia V, et al. Weekly docetaxel vs. docetaxel-based combination chemotherapy as second-line treatment of advanced non-small-cell lung cancer patients. The DISTAL-2 randomized trial. Lung Cancer. 2009;63(2):251-8. [pmid: 18632181].
134 Takeda K, et al. Phase III trial of docetaxel plus gemcitabine versus docetaxel in second-line treatment for non-small-cell lung cancer: results of a Japan Clinical Oncology Group trial (JCOG0104). Annals of Oncology. 2009;20(5):835-41. [pmid: 19164456].
135 Pallis AG, et al. A randomized phase III study of the docetaxel/carboplatin combination versus docetaxel single-agent as second line treatment for patients with advanced/metastatic non-small cell lung cancer. BMC Cancer. 2010;10:633. [pmid: 21092076].
136 Herbst RS, et al. Vandetanib plus docetaxel versus docetaxel as second-line treatment for patients with advanced non-small-cell lung cancer (ZODIAC): a double-blind, randomised, phase 3 trial. Lancet Oncology. 2010;11(7):619-26. [pmid: 20570559].
137 de Boer RH, et al. Vandetanib plus pemetrexed for the second-line treatment of advanced non-small-cell lung cancer: a randomized, double-blind phase III trial. Journal of Clinical Oncology. 2011;29(8):1067-74. [pmid: 21282537].
138 Natale RB, et al. Phase III trial of vandetanib compared with erlotinib in patients with previously treated advanced non-small-cell lung cancer. Journal of Clinical Oncology. 2011;29(8):1059-66. [pmid: 21282542].
139 Ciuleanu T, et al. Efficacy and safety of erlotinib versus chemotherapy in second-line treatment of patients with advanced, non-small-cell lung cancer with poor prognosis (TITAN): a randomised multicentre, open-label, phase 3 study. Lancet Oncology. 2012;13(3):300-8. [pmid: 22277837].
140 Maruyama R, et al. Phase III study, V-15-32, of gefitinib versus docetaxel in previously treated Japanese patients with non-small-cell lung cancer. Journal of Clinical Oncology. 2008;26(26):4244-52. [pmid: 18779611].
141 Kim ES, et al. Gefitinib versus docetaxel in previously treated non-small-cell lung cancer (INTEREST): a randomised phase III trial. Lancet. 2008;372(9652):1809-18. [pmid: 19027483].
142 Sekine I, et al. Quality of life and disease-related symptoms in previously treated Japanese patients with non-small-cell lung cancer: results of a randomized phase III study (V-15-32) of gefitinib versus docetaxel. Annals of Oncology. 2009;20(9):1483-8. [pmid: 19282468].
143 Lee DH, et al. Randomized Phase III trial of gefitinib versus docetaxel in non-small cell lung cancer patients who have previously received platinum-based chemotherapy. Clinical Cancer Research. 2010;16(4):1307-14. [pmid: 20145166].
144 Herbst RS, et al. Efficacy of bevacizumab plus erlotinib versus erlotinib alone in advanced non-small-cell lung cancer after failure of standard first-line chemotherapy (BeTa): a double-blind, placebo-controlled, phase 3 trial. Lancet. 2011;377(9780):1846-54. [pmid: 21621716].
145 Cullen MH, et al. A randomized phase III trial comparing standard and high-dose pemetrexed as second-line treatment in patients with locally advanced or metastatic non-small-cell lung cancer. Annals of Oncology. 2008;19(5):939-45. [pmid: 18283036].
146 Ready N, et al. Double-blind, placebo-controlled, randomized phase 2 study of the proapoptotic agent AT-101 plus docetaxel, in second-line non-small cell lung cancer. Journal of Thoracic Oncology: Official Publication of the International Association for the Study of Lung Cancer. 2011;6(4):781-5. [pmid: 21289522].
147 Ramlau R, et al. Phase III study comparing oral topotecan to intravenous docetaxel in patients with pretreated advanced non-small-cell lung cancer. J Clin Oncol. 2006;24(18):2800-7. [pmid: 16682727].
148 Paz-Ares L, et al. Phase III trial comparing paclitaxel poliglumex vs docetaxel in the second-line treatment of non-small-cell lung cancer. British Journal of Cancer. 2008;98(10):1608-13. [pmid: 18475293].
149 Krzakowski M, et al. Phase III trial comparing vinflunine with docetaxel in second-line advanced non-small-cell lung cancer previously treated with platinum-containing chemotherapy. Journal of Clinical Oncology. 2010;28(13):2167-73. [pmid: 20351334].
150 Schiller JH, et al. Pemetrexed with or without matuzumab as second-line treatment for patients with stage IIIB/IV non-small cell lung cancer. Journal of Thoracic Oncology: Official Publication of the International Association for the Study of Lung Cancer. 2010;5(12):1977-85. [pmid: 20978446].
151 Fossella FV, et al. Randomized phase III trial of docetaxel versus vinorelbine or ifosfamide in patients with advanced non-small-cell lung cancer previously treated with platinum-containing chemotherapy regimens. The TAX 320 Non-Small Cell Lung Cancer Study Group. J Clin Oncol. 2000;18(12):2354-62. [pmid: 10856094].
152 Garassino MC, et al. TAILOR: A phase III trial comparing erlotinib with docetaxel as the second-line treatment of NSCLC patients with wild-type (wt) EGFR. J Clin Oncol. 2012;30(suppl 2012 ASCO Annual Meeting):abstr LBA7501.
153 Von Pawel J, et al. A randomized phase II study of pemetrexed versus pemetrexed plus erlotinib in second-line treatment for locally advanced or metastatic, nonsquamous NSCLC. J Clin Oncol. 2011;29(suppl 2011 ASCO Annual Meeting):abstr 7526.
154 Tan F, et al. Icotinib (BPI-2009H), a novel EGFR tyrosine kinase inhibitor, displays potent efficacy in preclinical studies. Lung Cancer. 2012;76(2):177-82. [pmid: 22112293].
155 Cappuzzo F, et al. Erlotinib as maintenance treatment in advanced non-small-cell lung cancer: a multicentre, randomised, placebo-controlled phase 3 study. Lancet Oncology. 2010;11(6):521-9. [pmid: 20493771].
156 Qi W.-X, et al. Erlotinib and pemetrexed as maintenance therapy for advanced non-small- cell lung cancer: a systematic review and indirect comparison. Current Medical Research & Opinion. 2012;28(4):643-50. [pmid: 22414178].
157 Brodowicz T, et al. Cisplatin and gemcitabine first-line chemotherapy followed by maintenance gemcitabine or best supportive care in advanced non-small cell lung cancer: a phase III trial. Lung Cancer. 2006;52(2):155-63. [pmid: 16569462].
158 Belani CP, et al. Phase III study of maintenance gemcitabine (G) and best supportive care (BSC) versus BSC, following standard combination therapy with gemcitabine-carboplatin (G-Cb) for patients with advanced non-small cell lung cancer (NSCLC). J Clin Oncol. 2010;28(15s):supple; abstr 7506.
159 Perol M, et al. Maintenance with either gemcitabine or erlotinib versus observation with predefined second-line treatment after cisplatin-gemcitabine induction chemotherapy in advanced NSCLC: IFCT-GFPC 0502 phase III study. J Clin Oncol. 2010;28(15s):suppl; abstr 7507.
160 Brugger W, et al. Prospective molecular marker analyses of EGFR and KRAS from a randomized, placebo-controlled study of erlotinib maintenance therapy in advanced non-small- cell lung cancer. Journal of Clinical Oncology. 2011;29(31):4113-20. [pmid: 21969500].
161 Miller VA, Das A, Rossi M. A randomized, double-blind, placebo-controlled, phase IIIb trial (ATLAS) comparing bevacizumab (B) therapy with or without erlotinib (E) after completion of chemotherapy with B for first-line treatment of locally advanced, recurrent, or metastatic non-small cell lung cancer (NSCLC). [abstract no. LBA8002]. Journal of Clinical Oncology: ASCO annual meeting proceedings. 2009:407.
162 Kabbinavar FF, et al. Overall survival (OS) in ATLAS, a phase IIIb trial comparing bevacizumab (B) therapy with or without erlotinib (E) after completion of chemotherapy (chemo) with B for first-line treatment of locally advanced, recurrent, or metastatic non-small cell lung cancer (NSCLC). J Clin Oncol. 2010;28(15s):suppl; abstr 7526.
163 Surmont VF, et al. A double-blind, randomized, placebo-controlled phase III intergroup study of gefitinib (G) in patients (pts) with advanced NSCLC, non-progressing after first-line platinum-based chemotherapy (EORTC 08021-ILCP 01/03) [abstract]. Ann Oncol. 2010;21(suppl 8):viii. 124.
164 Ciuleanu T, et al. Maintenance pemetrexed plus best supportive care versus placebo plus best supportive care for non-small-cell lung cancer: a randomised, double-blind, phase 3 study. Lancet. 2009;374(9699):1432-40. [pmid: 19767093].
165 Fidias PM, et al. Phase III study of immediate compared with delayed docetaxel after front-line therapy with gemcitabine plus carboplatin in advanced non-small-cell lung cancer. Journal of Clinical Oncology. 2009;27(4):591-8. [pmid: 19075278].
166 Ciuleanu T, et al. Impact of induction chemotherapy on the outcome of treatment with pemetrexed in patients with advanced non-small-cell lung cancer: a retrospective analysis of a phase III trial [Abstract No. 256P]. Annals of Oncology. 2009:98.
167 Paz-Ares L, et al. Maintenance therapy with pemetrexed plus best supportive care versus placebo plus best supportive care after induction therapy with pemetrexed plus cisplatin for advanced non-squamous non-small-cell lung cancer (PARAMOUNT): a double-blind, phase 3, randomised controlled trial. Lancet Oncology. 2012;13(3):247-55. [pmid: 22341744].
168 Belani CP, et al. Quality of life in patients with advanced non-small-cell lung cancer given maintenance treatment with pemetrexed versus placebo (H3E-MC-JMEN): results from a randomised, double-blind, phase 3 study. Lancet Oncology. 2012;13(3):292-9. [pmid: 22336221].
169 Lee SM, et al. Randomized double-blind placebo-controlled trial of thalidomide in combination with gemcitabine and Carboplatin in advanced non-small-cell lung cancer. Journal of Clinical Oncology. 2009;27(31):5248-54. [pmid: 19770378].
170 Zhang L, et al. Gefitinib versus placebo as maintenance therapy in patients with locally advanced or metastatic non-small-cell lung cancer (INFORM; C-TONG 0804): a multicentre, double-blind randomised phase 3 trial. The Lancet Oncology. 2012.
171 Paz-Ares L, et al. PARAMOUNT: Final overall survival (OS) results of the phase III study of maintenance pemetrexed (pem) plus best supportive care (BSC) versus placebo (plb) plus BSC immediately following induction treatment with pem plus cisplatin (cis) for advanced nonsquamous (NS) non-small cell lung cancer (NSCLC). J Clin Oncol. 2012;30(suppl 2012 ASCO Annual Meeting):abstr LBA7507.
172 Bongers ML, et al. Cost effectiveness of treatment with new agents in advanced non-small- cell lung cancer: a systematic review. Pharmacoeconomics. 2012;30(1):17-34. [pmid: 22201521].
173 Wu B, et al. Cost-effectiveness of adding rh-endostatin to first-line chemotherapy in patients with advanced non-small-cell lung cancer in China. Clin Ther. 2011;33(10):1446-55. [pmid: 21992806].
174 Joerger M, et al. Addition of cetuximab to first-line chemotherapy in patients with advanced non-small-cell lung cancer: a cost-utility analysis. Ann Oncol. 2011;22(3):567-74. [pmid: 20843984].
175 Thongprasert S, et al. Cost-effectiveness analysis of cisplatin plus etoposide and carboplatin plus paclitaxel in a phase III randomized trial for non-small cell lung cancer. Asia Pac J Clin Oncol. 2011;7(4):369-75. [pmid: 22151987].
176 Ahn MJ, et al. Cost-effectiveness of bevacizumab-based therapy versus cisplatin plus pemetrexed for the first-line treatment of advanced non-squamous NSCLC in Korea and Taiwan. Asia Pac J Clin Oncol. Suppl 2. 2011;7:22-33. [pmid: 21585705].
177 Stanisic S, et al. Societal cost savings through bevacizumab-based treatment in non-small cell lung cancer (NSCLC). Lung Cancer. Suppl 1. 2010;69:S24-30. [pmid: 20727459].
178 Giuliani G, et al. Cost-effectiveness analysis of bevacizumab versus pemetrexed for advanced non-squamous NSCLC in Italy. Lung Cancer. Suppl 1. 2010;69:S11-7. [pmid: 20727457].
179 Bischoff HG, et al. Costs of bevacizumab and pemetrexed for advanced non-squamous NSCLC in Italy and Germany. Lung Cancer. Suppl 1. 2010;69:S18-23. [pmid: 20727458].
180 Goulart B, Ramsey S. A trial-based assessment of the cost-utility of bevacizumab and chemotherapy versus chemotherapy alone for advanced non-small cell lung cancer. Value Health. 2011;14(6):836-45. [pmid: 21914503].
181 Lewis G, et al. Cost-effectiveness of erlotinib versus docetaxel for second-line treatment of advanced non-small-cell lung cancer in the United Kingdom. J Int Med Res. 2010;38(1):9-21. [pmid: 20233509].
182 Bradbury PA, et al. Economic analysis: randomized placebo-controlled clinical trial of erlotinib in advanced non-small cell lung cancer. Journal of the National Cancer Institute. 2010;102(5):298-306. [pmid: 20160168].
183 Asukai Y, et al. Cost-effectiveness analysis of pemetrexed versus docetaxel in the second-line treatment of non-small cell lung cancer in Spain: results for the non-squamous histology population. BMC Cancer. 10:26. [pmid: 20113499].
184 Cromwell I, et al. Erlotinib or docetaxel for second-line treatment of non-small cell lung cancer: a real-world cost-effectiveness analysis. J Thorac Oncol. 2011;6(12):2097-103. [pmid: 22052223].
185 Horgan AM, et al. An economic analysis of the INTEREST trial, a randomized trial of docetaxel versus gefitinib as second-/third-line therapy in advanced non-small-cell lung cancer. Ann Oncol. 2011;22(8):1805-11. [pmid: 21273345].
186 Thongprasert S, Tinmanee S, Permsuwan U. Cost-utility and budget impact analyses of gefitinib in second-line treatment for advanced non-small cell lung cancer from Thai payer perspective. Asia Pac J Clin Oncol. 2012;8(1):53-61. [pmid: 22369444].
187 Vergnenegre A, et al. Cost-effectiveness of second-line chemotherapy for non-small cell lung cancer: an economic, randomized, prospective, multicenter phase III trial comparing docetaxel and pemetrexed: the GFPC 05-06 study. J Thorac Oncol. 2011;6(1):161-8. [pmid: 21150465].
188 Klein R, et al. Cost-effectiveness of pemetrexed as first-line maintenance therapy for advanced nonsquamous non-small cell lung cancer. J Thorac Oncol. 2010;5(8):1263-72. [pmid: 20581708].
189 Vergnenegre A, et al. Cross-market cost-effectiveness analysis of erlotinib as first-line maintenance treatment for patients with stable non-small cell lung cancer. Clinicoecon Outcomes Res. 2012;4:31-7. [pmid: 22347803].
190 Carlson JJ, et al. Budget impact of erlotinib for maintenance therapy in advanced non-small cell lung cancer. J Med Econ. 2011;14(2):159-66. [pmid: 21288059].
191 Matter-Walstra K, et al. Cost-effectiveness of maintenance pemetrexed in patients with advanced nonsquamous-cell lung cancer from the perspective of the Swiss health care system. Value Health. 2012;15(1):65-71. [pmid: 22264973].
192 Banz K, et al. Comparison of treatment costs of grade 3/4 adverse events associated with erlotinib or pemetrexed maintenance therapy for patients with advanced non-small-cell lung cancer (NSCLC) in Germany, France, Italy, and Spain. Lung Cancer. 2011;74(3):529-34. [pmid: 21592611].
193 Nuijten MJ, et al. A cross-market cost comparison of erlotinib versus pemetrexed for first-line maintenance treatment of patients with locally advanced or metastatic non-small- cell lung cancer. Lung Cancer. 2011.