# METHODS

## TOPIC DEVELOPMENT

This project was nominated by Michael J Kelley, MD, National Program Director for Oncology/MSS/PCS and Chief, Hematology/Oncology Durham VAMC, with input from a technical expert panel (TEP), including Oncology Field Advisory Committee Membership, Dr. Jennifer Malin -- Staff Physician, Oncology, West LA VA, and Dr. Apar Ganti -- Staff Physician, Oncology, Omaha VA.

The final key questions are:

Key Question #1 For patients with metastatic non-small cell lung cancer (NSCLC) what is the comparative effectiveness of the different recommended (e.g. NCCN guidelines) first line chemotherapy regimens?
Key Question #2 For patients with metastatic NSCLC what is the comparative effectiveness of the different recommended (e.g. NCCN guidelines) second line chemotherapy regimens?
Key Question #3 For patients with metastatic NSCLC what is the benefit of maintenance therapy following first line chemotherapy regimens compared with no maintenance therapy?
Key Question #4 What is the relative cost and cost-effectiveness of the different approaches in Key Questions 1–3?

## SEARCH STRATEGY

Preliminary searches done by the ESP coordinating center established that there is a very large literature on this topic, including numerous systematic reviews. With this knowledge, we employed a two-step search strategy. The first step was to identify recently published systematic reviews, and then the second step was to identify relevant clinical trials published subsequent to those reviews. We did not search conference abstracts specifically, although those that were identified in databases or through peer review were eligible for inclusion.

### Search #1 Systematic Reviews and Cost-Effectiveness Analyses

We searched PubMed and Cochrane databases for systematic reviews and cost-effectiveness analyses from 1/1/1966 through 3/16/2012, using standard search terms such as lung neoplasms, lung cancer, non-small-cell, non-small cell, non small cell, metastatic, metastasic, advanced, cost-effective, cost-benefit, cost analysis, and economic. We limited the search to peer-reviewed articles involving human subjects and published in the English language (Appendix A).

### Search #2 New Clinical Trials

Our second search identified trials by searching Medline (OVID), Embase, and Cochrane Register of Controlled Trials from 1/1/2007 through 5/8/2012, using search terms such as randomized controlled trial, carcinoma, non-small-cell, gemcitabine, etc. We limited the search to English language (Appendix B).

### Additional Strategies

We also obtained a list of key publications from the technical expert panel. Additionally, systematic reviews identified in the first search were reference mined for relevant trials.

## STUDY SELECTION

For the systematic reviews and cost-effectiveness analyses, titles obtained from the first search were reviewed in descending chronological order, starting with reviews published in 2012 and continuing backward. Given that the lag between end date of a search and publication is typically one year or more, we stopped this search at 2010, in order to capture the more recent reviews. Full-text articles of potentially relevant titles were retrieved, and each article was reviewed using the appropriate screener form (either systematic review or cost-effectiveness) in Appendix C. To be included, articles either had to present a systematic review or cost-effectiveness analysis, and had to present data on metastatic NSCLC, either for a range of stages, or more specifically for stage IIIB, IV, or advanced NSCLC. The systematic reviews also had to assess a first line, second line, or maintenance therapy. Exclusion criteria included duplicate publications, not presenting data on NSCLC, presenting data only for stage I or II NSCLC, or not capturing treatments of interest for the systematic reviews.

After having reviewed the existing systematic reviews, we determined that the best available existing review used a search ending in December 2007. We therefore conducted a second search, starting in January 2007, for all relevant clinical trials. For trials identified by this second search, titles were screened for relevance. Abstracts for included titles were then sorted by type of therapy: first line, second line, or maintenance. This corresponded with the first three key questions. The articles that did not address at least one of these types of therapy were excluded. Full-text articles were then retrieved for these trials.

Some literature prior to 2007 was included in the review because it came from our TEP or peer reviewers.

## DATA ABSTRACTION

We abstracted the following data for each included systematic review and cost-effectiveness analysis: Inclusion and exclusion criteria discussed above, type of therapy assessed, treatment captured/assessed, outcomes reported/used, and conclusions per abstract. For systematic reviews, we also abstracted the search end date, databases searched, and number of studies included. For cost-effectiveness analyses, we also abstracted whether the data were from a single study or multiple studies and what perspective the analysis was from (US payer, non-US payer, societal, or other).

For trials, the data abstracted depended on the Key Question, or sub-question, the article addressed. Potential types of data include: treatment/drug being assessed or compared, overall survival, response rate, sample size, study/setting, and conclusions per abstract.

## QUALITY ASSESSMENT

All studies included as evidence for key questions 1–3 are randomized trials or systematic reviews of randomized trials. For practical reasons, these cannot (in general) be blinded, as the dosing regimens are different for the various agents being compared (the exception being the some of the newer targeted therapies that can be taken orally). Using conventional metrics of quality assessment (randomization, blinding, withdrawals and dropouts) will not discriminate between studies except on the follow up rate, which has been recorded where applicable in the evidence tables. Where reported, the follow up rate is usually above 80 percent. Consequently, almost all studies in key questions 1–3 are considered approximately equivalent in terms of their risk of bias, and no subgroup analysis are performed that use risk of bias as a stratifying factor.

## DATA SYNTHESIS

For Key Question #1 (first-line therapy), we identified an existing systematic review from the Cancer Care Ontario Program in Evidence-Based Care (CCO) by Goffin and colleagues which was both comprehensive and good quality, and used this article as the basis for presenting data pertinent to first-line therapy.2 This report was divided into sub-questions, into which we sorted the systematic reviews and trials identified by our search strategies #1 and #2, detailed above. When the CCO had created evidence tables for a sub-question and our search identified new information relevant to that particular sub-question, these tables were reproduced and the new trials were added. Data were then narratively summarized for all sub-questions of interest.

For Key Question #2 (second-line therapy), we created three evidence tables. The first evidence table presents data for the relevant systematic reviews, including search end date, treatments being compared, included articles, outcomes reported, and conclusions per abstract. The second evidence table presents an abbreviated citation and whether or not the article was included in any of the systematic reviews for all articles identified by the second search and the TEP. The final evidence table presents data for trials not included in the existing identified systematic reviews, including number of patients randomized, agents being compared and patients in each of these treatment groups, median survival, one year survival, and overall response. We then narratively summarized evidence within each identified group of similar trials.

For Key Question #3 (maintenance therapy), we identified a good quality, comprehensive recent review by Zhang and colleagues.3 Analogous to what was done for first-line therapy, we searched for new relevant trials in addition to the existing review. The first evidence table presents data for the relevant systematic reviews, including search end date, treatments being compared, total trials and number of patients included, included articles, outcomes reported, and conclusions per abstract. The second evidence table presents data for trials identified by the second search and TEP that were not included in the existing systematic reviews. Data presented includes study or setting, type of therapy the maintenance is following, treatments being compared, outcomes reported, and results and conclusions per abstract.

For Key Question #4 (cost-effectiveness analyses), data are organized by therapy type (first-line therapy, second-line therapy, maintenance therapy, and other therapy). For each article, treatments assessed, data origin, analysis perspective, outcomes used, and conclusions per abstract are presented. After obtaining input from our TEP, we focused on specific cost-effectiveness analyses of greatest interest.

## RATING THE BODY OF EVIDENCE

We assessed the overall quality of evidence for outcomes using a method developed by the GRADE Working Group, which classified the grade of evidence across outcomes according to the following criteria:

- High = Further research is very unlikely to change our confidence on the estimate of effect.
- Moderate = Further research is likely to have an important impact on our confidence in the estimate of effect and may change the estimate.
- Low = Further research is very likely to have an important impact on our confidence in the estimate of effect and is likely to change the estimate.
- Very Low = Any estimate of effect is very uncertain.

Figure 1 A summary of GRADE’s approach to rating quality of evidence4

## PEER REVIEW

A draft version of this report was reviewed by four technical experts as well as clinical leadership. Their comments and our responses are presented in Appendix D.