# SEARCH STRATEGY FOR TRIALS (SEARCH #2)

## NON-SMALL CELL LUNG CANCER – RCTS SEARCH METHODOLOGY

DATABASE SEARCHED & TIME PERIOD COVERED:

Medline on OVID – 2007-5/8/2012

LANGUAGE:

English

SEARCH STRATEGY:

(systematic review? or systematic overview?).tw. OR meta-analysis/OR meta analysis.pt. OR metaanalys$.tw. OR meta analys$.tw. OR meta-analys$.tw. OR randomized controlled trials/or randomized controlled trial.pt. OR random allocation/OR (random$ and (trial* or stud$)).ti,ab

AND

carcinoma, non-small-cell lung/or nscls.ti,ab.OR (lung and (cancer$ or neoplasm$ or carcinom$ or malignan$ or tumo?r$)).ti,ab.

AND

(paclitaxel or taxol or docetaxel or taxotere or gemcitabine or gemzar or vinorelbine or navelbine or irinotecan or campto or camptosar or CPT-11 or pemetrexed or alimta or erlotinib or tarceva or gefitinib or iressa or bevacizumab or avastin or cetuximab or crizotinib).ti,ab.

NUMBER OF RESULTS: 772

DATABASE SEARCHED & TIME PERIOD COVERED:

Embase – 2007-5/8/2012

LANGUAGE:

English

SEARCH STRATEGY:

paclitaxel:ti OR taxol:ti OR docetaxel:ti OR taxotere:ti OR gemcitabine:ti OR gemzar:ti OR vinorelbine:ti OR navelbine:ti OR irinotecan:ti OR campto:ti OR camptosar:ti OR ‘cpt 11’:ti OR pemetrexed:ti OR alimta:ti OR erlotinib:ti OR tarceva:ti OR gefitinib:ti OR iressa:ti OR bevacizumab:ti OR avastin:ti OR cetuximab:ti OR crizotinib:ti OR paclitaxel:ab OR taxol:ab OR docetaxel:ab OR taxotere:ab OR gemcitabine:ab OR gemzar:ab OR vinorelbine:ab OR navelbine:ab OR irinotecan:ab OR campto:ab OR camptosar:ab OR ‘cpt 11’:ab OR pemetrexed:ab OR alimta:ab OR erlotinib:ab OR tarceva:ab OR gefitinib:ab OR iressa:ab OR bevacizumab:ab OR avastin:ab OR cetuximab:ab OR crizotinib:ab OR ‘paclitaxel’/exp OR paclitaxel

AND

((‘lung’/exp AND (cancer* OR neoplasm* OR carcinoma* OR malignan* OR tumor* OR tumour*) AND non:ti OR non:ab)) OR ‘lung non small cell cancer’/exp OR nsclc:ti OR nsclc:ab

AND

(randomized AND controlled AND trial*) OR (random AND allocation) OR (random* AND (trial* OR stud*))

AND

HUMAN

AND

‘article’/it OR ‘article in press’/it

NUMBER OF RESULTS: 659

DATABASE SEARCHED & TIME PERIOD COVERED:

Cochrane Register of Controlled Trials: 2007-5/8/2012

SEARCH STRATEGY:

“paclitaxel or taxol or docetaxel or taxotere or gemcitabine or gemzar or vinorelbine or navelbine or irinotecan or campto or camptosar or CPT-11 or pemetrexed or alimta or erlotinib or tarceva or gefitinib or iressa or bevacizumab or avastin or cetuximab or crizotinib in Title, Abstract or

Keywords

AND

non-small cell lung OR nonsmall cell lung OR nsclc in Title, Abstract or Keywords

NUMBER OF RESULTS: 516

TOTAL NUMBER OF RESULTS AFTER REMOVAL OF DUPLICATES & NON-RELEVANT MATERIAL (INCLUDING PHASE II TRIALS); 820