# SEARCH STRATEGY FOR SYSTEMATIC REVIEWS AND COST-EFFECTIVENES ANALYSES (SEARCH #1)

## TREATMENT OF METASTATIC NON-SMALL-CELL LUNG CANCER SEARCH METHODOLOGY

SEARCH STRATEGY #1 (SYSTEMATIC REVIEWS):

DATABASE SEARCHED & TIME PERIOD COVERED:

PubMed – 1966-3/16/2012

Cochrane Database of Systematic Reviews – All years

SEARCH STRATEGY (PUBMED):

lung neoplasms OR lung cancer

AND

non-small-cell OR non-small cell OR “non small cell”

AND

metastatic* OR metastasi* OR advanced

AND

Systematic[sb]

NUMBER OF RESULTS: 436

SEARCH STRATEGY (COCHRANE):

(Lung neoplasm* OR lung cancer):ti,ab,kw

AND

(Non-small cell OR “non small cell” OR non-small-cell):ti,ab,kw

NUMBER OF RESULTS: 13

SEARCH STRATEGY #2 (COST-EFFECTIVENESS):

DATABASE SEARCHED & TIME PERIOD COVERED:

PubMed – 1966-3/16/2012

Cochrane Economic Evaluations – All years

PUBMED:

lung neoplasms OR lung cancer

AND

non-small-cell OR non-small cell OR “non small cell”

AND

metastatic* OR metastasi* OR advanced

AND

cost OR costs OR cost-effective* OR cost-benefit OR cost utility OR cost-utilities OR cost analysis OR cost analyses OR economic OR economics

NOT

Results of Search #1

NUMBER OF RESULTS: 347

COCHRANE

(Lung neoplasm* OR lung cancer):ti,ab,kw

AND

(Non-small cell OR “non small cell” OR non-small-cell):ti,ab,kw

NUMBER OF RESULTS: 30