# SUMMARY AND DISCUSSION

## KEY FINDINGS

- Between 2011 and 2016, 11 studies reported on 8 mortality prediction models; all but one of the included studies (a study from Japan) utilized data from large electronic databases.
- Models were developed for different purposes, including development of individual risk scores to adjust for possible difference in mortality risk when comparing healthcare outcomes, to help primary care teams assess short-term risk of hospitalization or death without hospitalization, or help healthcare providers judge whether a patient will or won't die within a specified time pertinent to decisions about screening for cancer.
- C-statistics ranged from 0.77 to 0.90, indicating the models provide good discrimination of those who survived or died during the varying periods of follow-up. Few studies reported the sensitivity, specificity, or positive or negative predictive values for a proposed risk score threshold that would be used to determine which patients should or shouldn't be screened or treated.
- The prediction models were generally well-calibrated to the test samples with seemingly insubstantial differences between observed and predicted mortality across a range of risk groups.
- We found no true external validation studies of the reviewed mortality prediction models. None of the models have been externally validated for general primary care use.
- No studies meeting eligibility criteria for the review examined the impact of using one of the life expectancy calculators to improve on healthcare decisions or outcomes.

## LIMITATIONS

None of the life expectancy calculators under review were developed or validated specifically to estimate life expectancy (average survival times). The mortality prediction models can provide individual or average estimates of the probability of surviving for a specific period for a risk group that may be used as proxies for life expectancy. The range of individual estimates of survival probabilities within risk groups may be an important consideration when using the group average to estimate life expectancy, but often was not reported. Furthermore, the uncertainty inherent in personalized estimates may preclude their use, especially if a prediction model isn't based on a large number of patients that were followed for periods of clinical interest such as 5 or 10 years. The best way to communicate model predictions to providers and patients was not addressed. A number of disease-specific prediction models that were excluded from this review may be better-suited to disease-specific clinical decisions.

## APPLICABILITY OF FINDINGS TO THE VA POPULATION

Several of the prediction models listed in the KQ1 section seemingly could be adapted for use in VA primary care practices. The VA model of Wang et al (aka the Care Assessment Needs or CAN score) most likely could be modified to estimate the total mortality risk for time periods that are most relevant for specified clinical decisions.^12^ The work by Stefos et al supports the notion that the VA electronic records can be used to produce well-calibrated proxy estimates of life expectancy. ^8^ Several other studies support the impression that models based on patient demographics, the presence of life-threatening conditions, and perhaps history of healthcare utilization and other readily available variables can provide mortality estimates that have good, but less than perfect, predictive accuracy. The small numbers of quasi-validation studies suggest that the discrimination and calibration may vary when externally validated in VA primary care practices that may have substantially different distributions of the predictors and/or mortality. To adapt a mortality prediction model, the sources of data and definitions of predictor variables will need to be consistent across VA healthcare systems and over time. Centralized prediction models that are made widely available should be calibrated to and validated in several VA primary care patient populations and periodically checked for accuracy and recalibrated if necessary. The VA should consider models of survival curves that would provide estimates of life expectancy in addition to probabilities of survival.^4^

Although feasible, we found no studies to indicate whether making a reasonably accurate life expectancy calculator available to VA primary care providers or patients would influence their healthcare decisions or outcomes. A recent VA study by Tang et al suggested that having limited life expectancy as estimated by the investigators based on patients' age and Charlson comorbidity count was associated with an appropriately reduced rate of prostate-specific antigen screening for prostate cancer (39% when the estimated life expectancy was less than 5 years versus 77% with an estimated life expectancy of 10 or more years).^21^ Unfortunately, this study did not ascertain whether or how the clinicians estimated life expectancy or whether a VA effort to provide a validated quantitative calculator would influence their prognostic assessment or screening decisions.

## RESEARCH GAPS/FUTURE RESEARCH

Although healthcare providers and guidelines make recommendations based, in part, on assessments of life expectancy, there is no widely accepted statistical tool for estimating patients' life expectancy particularly for prolonged periods of 10 years. Research on the clinical usefulness and impact of life expectancy calculators on clinical decisions and outcomes is needed to guide further development and engender widespread acceptance. Hundreds of statistical prognostic tools have been developed, but are not being used in practice.^22,23^ Readily available statistical life expectancy estimates require both clinical face validity and proven accuracy for diverse decision-relevant risk groups and periods of time.^24^ Analytical life expectancy predictions have to be demonstrated to be more accurate than clinicians' intuitive prognostic assessments preferably using statistics that allow clinicians to compare prognostic errors. Additionally, they should use patient information that is readily and reliably available. Whether use of a standardized life expectancy calculator would reduce undesirable practice variation in regards to decisions involving estimates of life expectancy needs to be determined. Strong comparative evidence that using a quantitative prediction model can improve healthcare decisions and outcomes most likely will be needed to change current practices.

## CONCLUSIONS

Life expectancy calculators based on readily available electronic data that have acceptable performance for estimating one-, 5-, and 10-year life expectancy in middle age to older adults are feasible. These calculators need to be validated for use in primary care practices. There are no data on the effect of using these life expectancy calculators on patient or provider decisions or outcomes. If a life expectancy calculator is made available, it remains to be determined whether primary care providers would use it or whether it would improve healthcare delivery, resource use, patient experiences, or outcomes.