# RESULTS

## LITERATURE FLOW

Our literature search yielded 8,120 titles (Figure 2). Titles were reviewed by trained investigators and 509 studies were selected for abstract review. Each abstract was reviewed by 2 trained investigators and 51 studies were identified for full-text review. Full-text articles were reviewed by an investigator and the Principal Investigator. We included 10 studies from the literature search and an additional study identified from hand-searching studies included in the full-text review phase.

Figure 2 Literature Flow Chart

### Reviewed Studies

Table 1 summarizes the 11 eligible studies of 8 different mortality prediction models (see Appendix C, Tables 1 & 2 for more details). Six studies were done in the US. ^7-12^ Three were based on large Veterans Health Administration (VHA) electronic databases. ^8,11,12^ Others utilized Medicare data^7,9^ or local electronic health records.^10^ Four studies were from Canada using electronic administrative data representing the entire provinces of Ontario^13-15^ or Saskatchewan.^16^ One study from Japan used data collected by other studies combined with an extensive search for deaths.^17^ The median age of the Canadian provincial cohorts was in the mid-forties range, and over 60 in the other studies. All but the VA studies had approximately equal or greater inclusion of women and men. Only 2 studies examined race as a potential predictor. ^8,10^

Table 1 Study Population Characteristics^a^

Study | Location Year(s) | Population | Primary Data Source | Subjects
Austin 2011^15^ | Ontario, Canada 2007-08 | general adults | provincial health plan | n=10,498,413 median age 46 female 51%
Austin 2011^14^ | Ontario, Canada 2007-08 | general adults | provincial health plan | n=10,498,413 median age 46 female 51%
Austin 2012^13^ | Ontario, Canada 2007-08 | adults with schizophrenia | provincial health plan | n= 94,466 median age 47 female 54%
Gagne 2011^7^ | PA, NJ, USA 2004-05 | low income Medicare | Medicare & Pharmacy Assistance Programs | n=120,679 mean age 80 female 83%
Quail 2011^16^ | Saskatchewan, Canada 2001-02 | general adults | provincial health plan | n=662,423 median age 48 female 51%
Stefos 2012^8^ | USA 2007-08 | VHA healthcare | VHA electronic records | n=4,774,000 mean age 62 female 6%
Mathias 2013^10^ | Chicago, USA 2003-05 | multispecialty group practice | electronic health records (EPIC) | n=7,463 mean age 62 female 60%
Tan 2013^9^ | USA 1999-09 | 2000 Medicare enrollees | Medicare | n=1,137,311 mean age 76 female 60%
Ogata 2013^17^ | Kyushu Island, Japan 1999-09 | representative cohorts from other studies | study data plus extensive search for death records | n=2021 mean age 63 female 59%
Wang 2013^12,b^ | USA 2010-12 | VHA healthcare | VHA electronic records | n=4,598,408 mean age 64 female 6%
Wang 2012^11,b^ | USA 2009-10 | VHA healthcare with heart failure | VHA electronic records | n=198,640 mean age 73 female 2%

a Shaded rows are VHA studies

b VA Care Assessment Needs (CAN) model

As summarized in Table 2, 4 of the mortality prediction models presented in 6 articles were developed to calculate individual risk scores to adjust for possible differences in mortality risk when comparing healthcare outcomes in different groups of patients.^7,8,13-16^ One VHA model was developed to help primary care teams assess the short-term risk of hospitalization or death without hospitalization.^11,12^ Three prediction models were developed to help healthcare providers judge whether patients would or would not die within a specified time.^9,10,17^ All of the prediction models incorporated the patients' age and sex and all except one^17^ included selected diagnoses. All of the predicted models that incorporated diagnosis codes used a method to group ICD-9 or ICD-10 diagnosis codes into predictor variables, except Mathias 2013.^10^ A varying number included other demographic and clinical assessments such as vital signs, laboratory results, and prescription medications as predictor variables.

Table 2 Description of Prediction Models^a^

Study | Intended Use | Types of Predictors | Mortality being Predicted (mortality%)
Austin 2011^15^ | Statistical risk adjustment | Patients' age, sex, and diagnoses^b^ recorded in previous 2 years | Death within 1 year (0.8%) Subgroup age > 65 (NR)
Austin 2011^14^ | Statistical risk adjustment | Patients' age, sex, and diagnoses^b^ recorded in previous 2 years | Death within 1 year (0.8%)
Austin 2012^13^ | Statistical risk adjustment | Patients' age, sex, and diagnoses^b^ recorded in previous 2 years | Death within 1 year (2.0%)
Gagne 2011^7^ | Statistical risk adjustment | Patients' age, sex, and diagnoses^c^ recorded in previous year | Death within 1 year (7.5%)
Quail 2011^16^ | Statistical risk adjustment | Patients' age, sex, income, region, and diagnoses^c^ recorded in previous year | Death within 1 year (1.3%) Subgroup age > 65 (5.1)
Stefos 2012^8^ | Statistical risk adjustment | Selected patient demographics and diagnoses,^d^ including chronic disease registries, in previous year | Death within 1 year (5.5%)
Mathias 2013^10^ | Health care decision | Selected patient demographics, diagnoses, vital signs, laboratory test results, medications, and prior healthcare utilization in prior 1-2 years | Death within 5 years (11%)
Tan 2013^9^ | Health care decision | Patients' age, sex, and diagnoses,^c^ and healthcare utilization recorded in previous year | Death within 10 years (women 51%; men 57%)
Ogata 2013^17^ | Health care decision | Cardiovascular risk: factors age, sex, smoking, blood pressure, cholesterol, glycated hemoglobin | Death within 10 years (site 1 13%; site 2 28%)
Wang 2013^12e^ | Identify patients at higher risk of hospitalization taking competing risk of death into account | Selected patient demographics, diagnoses, vital signs, laboratory test results, medications, and prior healthcare utilization in previous year | Death without hospitalization within 90 days (0.7%) & 1-year 2.8%)
Wang 2012^11e^ | Identify patients at higher risk of hospitalization taking competing risk of death into account | Selected patient demographics, diagnoses,^b,d^ vital signs, laboratory test results, medications, and prior healthcare utilization in previous year | Death without hospitalization within 30 days (0.9%) & 1-year (7.1%)

a Shaded rows are VHA studies

b Diagnosis codes grouped using Aggregated Diagnosis Group software

c Diagnosis codes grouped into Charlson & Elixhauser categories

d Diagnosis codes grouped using Hierarchical Coexisting Conditions

e VA Care Assessment Needs (CAN) model

NR = not reported

Models developed for mortality risk adjustment focused on mortality during the first year of follow-up, when the overall mortality ranged from < 1% to 7.5% depending on the types of patients selected for the study. Other models focused on whether patients would be expected (predicted) to live for time horizons of 5 or 10 years.^9,10,17^ These longer time horizons had higher mortality. To assess care needs, Wang et al modeled deaths that occurred without a hospitalization within one year rather than total all-cause mortality, but did so using VHA data.^11,12^ Presumably the same data could be utilized to model total mortality.

### Study Quality

Most studies were judged to have acceptable quality based on meeting at least 4 of the 5 criteria (Table 3). The extent of missing predictor variables often was not reported, presumably because a relatively small proportion of subjects with missing predictor values were excluded from model development and validation. The Ogata study that utilized data from 2 previous cohort studies had extensive amounts of missing data predictor values for one study site and the completeness of the post hoc searches for dates of death in the community wasn't clear.^17^

Table 3 Quality of Included Studies^a^

Study author, year | Predictor definition or measurement same for deceased/survivors | Outcome definition or measurement same for deceased/survivors | Outcome assessed independent of predictors (eg, blinded) | Incomplete follow-up or missing predictor data (%, handling of) | Method of validation | Overall quality
Austin, 2011^15^ | Yes | Yes | Yes | NR | Assessed over fitting by bootstrap methods | Acceptable
Austin, 2011^14^ | Yes | Yes | Yes | NR | Assessed over fitting by bootstrap methods | Acceptable
Austin, 2012^13^ | Yes | Yes | Yes | NR | Application of previously developed model for general adult population | Acceptable
Gagne, 2011^7^ | Yes | Yes | NR | NR | External sample | Acceptable
Quail, 2011^16^ | Yes | Yes | Yes | Missing income imputed | External sample & time | Acceptable
Stefos, 2012^8^ | Yes | Yes | Yes | NR | Copas test for overfitting (repeated, split sample, cross-validation design) | Acceptable
Mathias, 2013^10^ | Yes | Yes | Yes | NR | 10-fold cross validation | Acceptable
Tan, 2013^9^ | Yes | Yes | Yes | NR | Random split sample | Acceptable
Ogata, 2013^17^ | Yes | Yes | NR | 3.6% missing data/lost at site 1; 80% excluded at site 2 due to missing data/lost or < 10 years follow-up | 1) Split sample (random) from first site and 2) second site only served as validation site | Unacceptable
Wang, 2013^12b^ | Yes | Yes | Yes | Yes | Randomly split sample | Acceptable
Wang 2012^11b^ | Yes | Yes | Yes | Yes | Randomly split sample | Acceptable

a Shaded rows are VHA studies

b VA Care Assessment Needs (CAN) model

NR = not clearly reported

## KEY QUESTION 1 Between 2011 and 2016, have there been any additional reports of life expectancy calculators that may have sufficient predictive accuracy for use in adult primary care practice?

### Summary of Findings

Most studies reported a range of estimated probabilities of dying that included some values greater than 0.5 (50%) that could be interpreted as having a life expectancy less than the model's time horizon (Table 4). Wang et al modeled death without a hospitalization, thus their model cannot be used as is to estimate life expectancy.^11,12^ However, as noted previously, most likely their prediction model could be adapted to do so.

Table 4 Predictive Performance of Models under Review^a^

Study | Estimated Probabilities of Dying | Discrimination | Calibration†
Austin 2011^15^ | 0.00 to 0.90 | C-statistic: 0.92 | Differences between observed and predicted mortality <1% in all 100 risk categories except top 3 where differences < 3%
Austin 2011b^b,14^ | 0.00 to 0.90 | C-statistic: 0.92 | Differences between observed and predicted mortality ∼1% in in all 20 risk categories
Gagne 2011^7^ | Mean of 1^st^ decile 0.03 to 10^th^ decile 0.55 | C-statistic: 0.79 | Under predicted by ∼ 3% in 5^th^ & 6th deciles with 20 -25% mortality, over predicted by ∼ 10% in 10th decile with ∼ 45% mortality, otherwise observed and predicted mortality % within ∼1%
Quail 2011^16^ | NR | C-statistic with Charlson comorbidities: 0.90 C-statistic with Elixhauser comorbidities: 0.91 | NR
Stefos 2012^8^ | Mean of 1^st^ decile 0.025 to 10^th^ decile 0.94 | C-statistic: 0.86 | Ratio of observed to predicted number of deaths by predicted risk decile
Stefos 2012^8^ | Mean of 1^st^ decile 0.025 to 10^th^ decile 0.94 | C-statistic: 0.86 | [underlined: Predicted] | [underlined: O/P ratio]
Stefos 2012^8^ | Mean of 1^st^ decile 0.025 to 10^th^ decile 0.94 | C-statistic: 0.86 | 2.5% | 0.94
Stefos 2012^8^ | Mean of 1^st^ decile 0.025 to 10^th^ decile 0.94 | C-statistic: 0.86 | 13% | 1.12
Stefos 2012^8^ | Mean of 1^st^ decile 0.025 to 10^th^ decile 0.94 | C-statistic: 0.86 | 24% | 1.12
Stefos 2012^8^ | Mean of 1^st^ decile 0.025 to 10^th^ decile 0.94 | C-statistic: 0.86 | 34% | 1.06
Stefos 2012^8^ | Mean of 1^st^ decile 0.025 to 10^th^ decile 0.94 | C-statistic: 0.86 | 45% | 0.98
Stefos 2012^8^ | Mean of 1^st^ decile 0.025 to 10^th^ decile 0.94 | C-statistic: 0.86 | 55% | 0.95
Stefos 2012^8^ | Mean of 1^st^ decile 0.025 to 10^th^ decile 0.94 | C-statistic: 0.86 | 65% | 0.91
Stefos 2012^8^ | Mean of 1^st^ decile 0.025 to 10^th^ decile 0.94 | C-statistic: 0.86 | 75% | 0.87
Stefos 2012^8^ | Mean of 1^st^ decile 0.025 to 10^th^ decile 0.94 | C-statistic: 0.86 | 85% | 0.87
Stefos 2012^8^ | Mean of 1^st^ decile 0.025 to 10^th^ decile 0.94 | C-statistic: 0.86 | 94% | 0.86
Mathias 2013^10^ | Mean of 1^st^ decile 0.036 to 10^th^ decile 0.55 | C-statistic: 0.86 Sensitivity/specificity using cut-off for predicted probability of dying within 5 years = 0.5 (50%): 31%/98% Positive/negative predictive value using cut-off for predicted probability of dying within 5 years = 0.5 (50%): 63%/92% | Differences between observed and predicted mortality <3% across all deciles of predicted risk
Tan 2013^9^ | 1^st^ quartile < 0.25 to 4^th^ quartile > 0.75 | C-statistic at 10 years: Women: 0.79 Men: 0.7 Positive predictive value for LE < 10 years for women/men: ∼75%/75% | Observed mortality within quartiles of predicted probabilities for women/men: 1st quartile: 17%/20% 2nd quartile: 35%/35% 3rd quartile: 65%/64% 4th quartile: 88%/90%
Ogata 2013^17^ | Predicted to die in 10 years: Site 1: 36/365 (9.9%) Site 2: 35/170 (20.6%) | C-statistic Site 1:0.83 Site 2: 0.85 | Difference between observed and predicted mortality: Site 1:3.5% Site 2: 7.6%
Wang 2013^12,c,d^ | 1-year mean of 1^st^ decile <0.01 to 10^th^ decile ∼0.14 | C-statistic: 0.85 | Differences between observed and predicted in each decile of predicted probabilities: negligible Observed deaths if in upper 5% of 1-year predicted probabilities of death without hospitalization: 19.4%

a Shaded rows are VHA studies

b Same prediction model as Austin 2011^15^ except regression coefficients converted to a single weighted Mortality Risk Score

c Only predicting deaths without hospitalization, not total deaths

d VA Care Assessment Needs (CAN) model

NR = not reported

The reported C-statistics ranged from 0.77^9^ to over 0.90^15,16^ indicating that the models discriminated those who survived or died by rank ordering subjects according to their risk of dying, but not perfectly. The latter 2 studies achieved these high levels of discrimination using the patient's age and gender in combination with diagnostic codes extracted from large provincial health plan databases to predict 1-year mortality. These very high levels of discrimination most likely were related to inclusion of a large proportion of younger adults that would be less likely to die than older adults. In contrast, Gagne et al, who used similar predictors extracted from state health plan databases, only had a C-statistic of 0.79 in a more elderly sample of patients with higher mortality at one year.^7^ Tan et al also used similar predictors extracted from Medicare data; however their lower C-statistic is for deaths that occurred over a much longer 10-year time span (these are inherently more difficult to estimate than a shorter time span due to interim changes in predictors and health).^9^ Using Tan et al's 10-year mortality prediction model, over 80% of the subjects that had a predicted 10-year probability of dying that was greater than 0.75 (75%) died within this time interval whereas approximately 65% with a 10-year probability of dying between 0.50 to 0.74 died. The positive and negative predictive values were 63% and 92% using a cut-off for Mathias et al's predicted probability of dying within 5 years equal to 0.5 (50%).^10^ Other reports did not focus on any particular risk score threshold to predict survival and therefore did not estimate sensitivity, specificity, or predictive values.

The differences between observed and predicted mortality in subjects that were grouped according to their estimated probabilities of dying were mostly small, that is, the prediction models were well-calibrated to the test sample. Thus, if a clinician used the prediction model to place a patient in a mortality risk group, the observed mortality in the group most likely would be similar to the risk group's average or median predicted mortality. If a risk group's individual estimated probabilities of dying within the specified follow-up time are all either greater than or less than 0.5, as a proxy one might say their life expectancy is either less than or greater than the specified follow-up time, respectively.

### Conclusion for Key Question #1

Since 2011 several life expectancy calculators have been reported that may have sufficient predictive accuracy for general use in adult primary care practice. Accurate proxy life expectancy calculators can be developed using age, gender, and diagnosis codes and perhaps a few other select variables obtained from administrative or electronic medical records. However, all of the models under review would require some adaptation before being made available to VA primary care providers. Few studies reported the sensitivity, specificity, or positive or negative predictive values for a risk threshold proposed for a clinical decision such as whether a patient should or shouldn't be screened or treated.

### Rating for the Strength of Evidence for KQ1: High

Several prediction models utilizing variables that are generally available in electronic medical records had consistently good predictive accuracy.

## KEY QUESTION 2 Of the life expectancy calculators being reviewed, have any external validation studies been published between 2011 and 2016? If yes, what population was studied and what was the predictive accuracy therein?

### Summary of Findings

Our review didn't find any true validation studies. We found 2 separate quasi-validation reports^11,13^ and 2 elderly subgroup analyses.^12,15^ The predictive performance in these patient subgroups is summarized in Table 5. Regression coefficients for the predictor variables were re-estimated for the 2 elderly subgroup analyses^12,15^ and the Wang et al study of patients with heart failure prior to examining the predictive accuracy in the subpopulations.^11^ Compared to the mortality prediction models for general adult patient populations, both the Austin and Wang models had poorer discrimination of survivors and decedents in the elderly and schizophrenic or heart failure subpopulations. Calibration of the Austin model was poorer in the schizophrenic subpopulation whereas after recalibration the calibration of the Wang model was maintained in the elderly and heart failure subpopulations.

Table 5 Validation of Mortality Prediction Models^a^

Study | Population Subgroup | Number Mortality | Discrimination | Calibration
Austin 2011^15^ | Age ≥ 65 years | n=NR 1–year NR | C-statistic: 0.81 | Differences between observed and predicted mortality NR
Austin 2012^13^ | Schizophrenia | n=94,466 1–year 2.0% | C-statistic: 0.84 | Differences between observed and predicted mortality NR, however calibration plots indicated significantly worse calibration
Wang 2013^12,b,c^ | Age > 65 years | n=2,129,063 1–year ∼4.7% | C-statistic: 0.80 | Small differences between observed and predicted in each decile of predicted probabilities
Wang 2012^11,b,c^ | Heart failure | n=198,640 1–year 7.1% | C-statistic: 0.76 | Differences between observed and predicted mortality % in each decile of predicted probabilities were negligible

a Shaded rows are VHA studies

b Only predicting deaths without hospitalization, not total deaths

c VA Care Assessment Needs (CAN) model

NR = not reported

### Conclusion for Key Question #2

Discrimination of the deceased versus surviving patients was reduced in these more homogenous subpopulations with higher mortality than the overall general populations. Calibration of the prediction models was not always as good in the subpopulations despite recalibration. The calibration of a mortality prediction model should be examined in a representative sample of the primary care practice in which it will be used, and the predictive accuracy should be validated using time horizons that are commensurate with the clinical decisions it will support.

### Rating for the Strength of Evidence for KQ2: Insufficient

None of the 4 studies were true validation studies that examined the predictive performance in external samples of primary care practices.

## KEY QUESTION 3 What is the clinical use of the mortality prediction models (aka life expectancy calculators), and was there improvement in patient survival times, health-related quality of life, provider-patient communication, patient satisfaction and participation in clinical decisions, or lower healthcare utilization and costs?

### Summary of Findings

We found no studies that examined the effects of using the reviewed mortality prediction models in clinical care.

We found 2 reports that alluded to use of other life expectancy calculators. One study retrospectively evaluated the potential impact of a previously developed 4-year life expectancy calculator (Health and Retirement Study Mortality Risk Index^18^).^19^ A retrospective patient cohort of 8,090 that was age 65 and older at the time of their last visit to a primary care practice in 2003-04 was studied. The prediction model identified 1,241 of the 8,090 (15%) as having a 40 to 70% probability of dying within 4 years. Their observed mortality was 670/1,241 (54%); thus, the authors concluded it would have been reasonable for these patients to forego a screening colonoscopy due to their limited life expectancy. Whether the primary care providers and patients would have come to the same conclusion with or without the life expectancy calculator was not determined.

Clinicians in the United Kingdom developed a 3-year mortality risk calculator for elderly patients with breast cancer to help determine whether they should undergo surgical (if expected to live at least 3 years) or medical therapy.^20^ Their disease-specific prediction model (not included in this review) incorporated the American Society of Anesthesiologists (ASA) grade, age, ethnicity, bilateral or previous contralateral breast cancer, and nurse administered questionnaires to obtain the Charlson comorbidity score, Mini Mental State Examination score, Geriatric Depression Scale score, and Barthel and Instrumental Indexes of Activities of Daily Living. The prediction model was used in a Co-morbidity Clinic for patients who were potentially unfit or declined standard treatment for breast cancer, and was reportedly useful for shared decision-making about treatment. The report did not state exactly how the risk model was employed or communicated to patients or actually study its impact on the treatment decision.

### Conclusion for Key Question #3

We found no studies of the effects of the reviewed mortality prediction models on clinical decisions and outcomes. Clinical outcome studies of evaluating life expectancy calculator for clinical decision-making are needed to support their implementation by healthcare organizations and use by clinicians and patients. Studies should focus on a well-defined clinical decision in the applicable population, for example, decisions about cancer screening based on 10 year life expectancy or palliative care based on life expectancy less than 6-12 months.

### Rating for the Strength of Evidence for KQ 3: Insufficient