# REFERENCES

1 Schoenborn NL, Bowman TL, Cayea D, Pollack CE, Feeser S, Boyd C. Primary care prectitioners' views on incorporating long-term prognosis in the care of older adults. JAMA Intern Med. 2016; 176(5):671-678.27064895
2 Yourman L, Lee S, Schonberg M, Widera E, Smith A. Prognostic indices for older adults: a systematic review. JAMA. 2012;307(2): 182-192.22235089
3 Minne L, Ludikhuize J, de Rooij SE, Abu-Hanna A. Characterizing predictive models of mortality for older adults and their validation for use in clinical practice. J Am Geriatr Soc. 2011;59(6):1110-1115.21649618
4 Lee SJ, Boscardin J, Kirby KA, Covinsky KE. Individualizing life expectancy estimates for older adults using the Gompertz Law of Human Mortality. PLOS One. 2014;9(9):e108540.25265291
5 Baade PD, Youlden DR, Andersson TML, . Estimating the change in life expectancy after a diagnosis of cancer among the Australian population. BMJ Open. 2015;5:e006740.
6 Moons K, de Groot J, Bouwmeester W, . Critical appraisal and data extraction for systematic reviews of prediction modelling studies: the CHARMS checklist. PLOS Med. 2014;11(10):e1001744.25314315
7 Gagne JJ, Glynn RJ, Avorn J, Levin R, Schneeweiss S. A combined comorbidity score predicted mortality in elderly patients better than existing scores. J Clin Epidemiol. 2011;64(7):749-759.21208778
8 Stefos T, Lehner L, Render M, Moran E, Almenoff P. Determining population based mortality risk in the Department of Veterans Affairs. Health Care Manag Sci. 2012;15(2):121-137.22167323
9 Tan A, Kuo YF, Goodwin JS. Predicting life expectancy for community-dwelling older adults from Medicare claims data. Am J Epidemiol. 2013;178(6):974-983.23851579
10 Mathias JS, Agrawal A, Feinglass J, Cooper AJ, Baker DW, Choudhary A. Development of a 5 year life expectancy index in older adults using predictive mining of electronic health record data. J Am Med Inform Assoc. 2013;20(e1):e118-124.23538722
11 Wang L, Porter B, Maynard C, . Predicting risk of hospitalization or death among patients with heart failure in the veterans health administration. Am J Cardiol. 2012;110(9):1342-1349.22819429
12 Wang L, Porter B, Maynard C, . Predicting risk of hospitalization or death among patients receiving primary care in the Veterans Health Administration. Med Care. 2013;51(4):368-373.23269113
13 Austin PC, Newman A, Kurdyak PA. Using the Johns Hopkins Aggregated Diagnosis Groups (ADGs) to predict mortality in a population-based cohort of adults with schizophrenia in Ontario, Canada. Psychiatry Res. 2012;196(1):32-37.22364931
14 Austin PC, van Walraven C. The mortality risk score and the ADG score: two points-based scoring systems for the Johns Hopkins aggregated diagnosis groups to predict mortality in a general adult population cohort in Ontario, Canada. Med Care. 2011;49(10):940-947.21921849
15 Austin PC, van Walraven C, Wodchis WP, Newman A, Anderson GM. Using the Johns Hopkins Aggregated Diagnosis Groups (ADGs) to predict mortality in a general adult population cohort in Ontario, Canada. Med Care. 2011;49(10):932-939.21478773
16 Quail JM, Lix LM, Osman BA, Teare GF. Comparing comorbidity measures for predicting mortality and hospitalization in three population-based cohorts. BMC Health Serv Res. 2011;11:146.21663672
17 Ogata K, Miyamoto T, Adachi H, . New computer model for prediction of individual 10-year mortality on the basis of conventional atherosclerotic risk factors. Atherosclerosis. 2013;227(1): 159-164.23369703
18 Lee S, Lindquist K, Segal M, Covinsky K. Development and validation of a prognostic index for 4-year mortality in older adults. JAMA. 2006;295(7):801-808.16478903
19 Synnestvedt MB, Weiner MG. Evaluation of the use of electronic health data to classify four-year mortality risk for older adults undergoing screening colonoscopies. Proc AMIA Symp. 2011;2011:1361-1365.22195198
20 Stotter A, Reed MW, Gray LJ, Moore N, Robinson TG. Comprehensive Geriatric Assessment and predicted 3-year survival in treatment planning for frail patients with early breast cancer. Br J Surg. 2015;102(5):525-533.25708660
21 Tang V, Shi Y, Fung K, . Clinician factors associated with prostate-specific antigen screening in older veterans with limited life expectancy. JAMA Intern Med. 2016.
22 Wyatt J, Altman D. Commentary: prognostic models: clinically useful or quickly forgotten? BMJ. 1995;311:1539-1541.
23 Siontis G, Tzoulaki I, Ioannidis J. Predicting death: an empirical evaluation of predictive tools for mortality. Arch Intern Med. 2011;171(19):1721-1726.21788535
24 Moons K, Altman D, Vergouwe Y, Royston P. Prognosis and prognostic research: application and impact of prognostic models in clinical practice. BMJ. 2009;338:b606.19502216