# METHODS

## TOPIC DEVELOPMENT

The topic was nominated by Dr. David MacPherson (Chief Medical Officer, VISN4). Drs. Stephan Fihn (Office of Analytics and Business Intelligence) and Joe Francis (Clinical Analytics and Reporting) were consulted and agreed to be operational partners for the review. The key questions and scope of the review were developed with input from the operational partners and a Technical Expert Panel.

## SEARCH STRATEGY

We searched MEDLINE (Ovid) from 2011 to May 2016 using title words for life expectancy, calculators or models, survival, mortality, death, and validation or calibration. The search was limited to English language and studies of humans middle-aged (45 plus years) and older. We also limited the search to relevant study designs. The full search strategy is presented in Appendix A.

## STUDY SELECTION

The following conceptual framework (Figure 1) guided study selection.

Figure 1 Conceptual Framework

The conceptual basis for this review was that a decision support tool would be electronically implemented to provide quantitative survival estimates to primary care providers who along with their patients would use the estimates when making healthcare decisions and hopefully improve patient outcomes and the efficiency of healthcare. For example, healthcare providers might place patients into risk groups that would be treated differently or they might somehow share the estimates with patients. Either individual or risk group estimates of life expectancy or probabilities of survival or dying within a specified period of time were of interest.

The methods of estimation had to be generally applicable to primary care patient populations. Hence a large numbers of disease- or cause-specific mortality prediction models were excluded. Included studies had to offer a method of estimation based on variables that would be generally available for outpatients. Estimates that require inpatient variables that would only be available for a minority of primary care patients were excluded. Likewise studies of novel biomarkers or individual predictors, including those based on only age, sex, and race, were excluded. Reports of predictive values (percentage of predictions that were correct), including group survival curves, observed versus predicted survival/mortality (aka calibration), and sensitivity or specificity of predictions were considered to be most pertinent to clinical decision-makers and thus this review. Studies that were limited to tests for associations such as relative risks, odds ratios, and hazard ratios were considered to be too preliminary for inclusion in this review.

Studies of the clinical use of survival estimates were of particular interest. For example, estimates might be used to help providers and patients make a specified decision about prevention or treatment. Estimates might be used to help healthcare providers prioritize their patients for medical evaluation or services according to the expected net benefit based, in part, on life expectancy. Clinical trials might have used the prediction model to help select or identify patients for whom a treatment is most likely to be of benefit or least likely to harm.

The effects of applying prognostic estimates on patients' survival and/or health-related quality of life are the ultimate outcomes of interest. In addition, we sought studies of the effects of using survival estimates on healthcare utilization, costs, and patient satisfaction or participation in healthcare decisions.

## DATA ABSTRACTION

Data were abstracted into evidence tables by one trained investigator and verified by the principal investigator. We abstracted information on study characteristics (country, study dates, source of data, participants, mortality) and model characteristics and performance (intended use of model, predictors, timing of predictor and survival assessments, modelling method, methods used to select predictors, mortality risk groups, and predictive performance).

## QUALITY ASSESSMENT

Quality of individual studies was assessed using selected items from the [underlined: CH]ecklist for critical [underlined: A]ppraisal and data extraction for systematic [underlined: R]eviews of prediction [underlined: M]odelling [underlined: S]tudies (CHARMS).^6^ Five criteria were selected: 1) predictor definition/measurement, 2) outcome definition/measurement, 3) independence of outcome and predictor assessments, 4) completeness of follow-up/predictor data, and 5) validation.

## DATA SYNTHESIS

The evidence is narratively described without any formal meta-analysis.

## RATING THE STRENGTH OF EVIDENCE

The strength of evidence for each key question is rated as high, low, or insufficient based on the number of quality studies and the consistency of the results.

## PEER REVIEW

A draft version of this report was reviewed by content experts as well as clinical leadership. Reviewer's comments and our responses are presented in Appendix B and the report was modified accordingly.