# INTRODUCTION

Life expectancy, an estimate of the number of remaining years of life a person has, is an important consideration for making clinical decisions in primary care. For example, colorectal cancer screening guidelines state that clinicians should only screen patients with an estimated life expectancy of at least 10 years because otherwise benefits of cancer detection are unlikely to outweigh the harms and costs. Referral to hospice care is often based on a life expectancy of less than 6 months. Implantable cardiac defibrillators are not indicated if the patient is not expected to live longer than one year.

Most currently available life expectancy calculators or life tables are based on a person's age, gender, and race. These calculators may not be widely used in clinical practice because clinicians usually consider other key factors such as the presence and severity of life-threatening diseases and functional status. Given the uncertainty inherent in formulating a prognosis and desire to avoid prognostic errors, clinical prognostic assessments are often qualitative, such as thinking a patient has a ‘higher’ risk of dying, and often are not shared with patients.^1^ In contrast, survival prediction models typically incorporate a number of variables to calculate a quantitative estimate of the patient's probability of surviving or dying during a specified period of time.

This systematic review focused on identifying and evaluating reports of multivariable quantitative prediction models (aka calculators) of all-cause mortality published in 2011 and thereafter. Others have reviewed reports of predictive models for older patients from before 2011.^2,3^ These previous reviews listed a large number of prediction models that are available for primary care or population-based settings. However, the reviewers stated the evidence was insufficient to support their widespread clinical use. Of interest for this review were prediction models of all-cause mortality that would generally be applicable to most patients seen in primary care practices without off-putting effort by clinicians to ascertain the predictor variables and calculate the estimates. In addition, we were interested in reports that provided assessments of a proposed model's predictive accuracy, external validity, and ideally impact on clinical decision-making and patient outcomes. The ultimate goal is to identify and evaluate life expectancy calculators that primary care providers would be willing and able to use and share with their patients to improve participation and satisfaction with clinical decisions that are based, in part, on life expectancy. Ultimately, efforts to make a validated and accurate life expectancy calculator readily available to clinicians will need to demonstrate benefits in terms of improving healthcare outcomes and efficiency as well as patient experiences.

The Key Questions for this review and our approach to evaluating the pertinent evidence were as follows.

## KQ1 Between 2011 and 2016, have there been any additional reports of life expectancy calculators that may have sufficient predictive accuracy for use in adult primary care practice?

Most mortality prediction models are not used to calculate a patient's life expectancy (number of years of life remaining on average) per se. Rather they estimate probabilities of surviving or dying within a specified period of time. If all patients being studied were followed to the end of a time period of interest, for example, 5 years, then multivariable logistic regression models are typically used to estimate a patient's probability of dying before the end of the period. As a proxy for life expectancy, one might say if one's estimated probability of dying within 5 years is greater than 0.5 (50%), one's life expectancy is less than 5 years.

During development of mortality prediction models, the estimated probabilities of dying are often arbitrarily categorized into risk groups, and the predicted number of deaths in each risk group is compared to the observed number. If the differences are small, the prediction model was well-calibrated to the studied sample. Primary care providers may be more willing to use a well-calibrated model, especially if patients placed in particular well-calibrated risk groups would be treated differently (presumably because the intervention has a different likelihood of benefiting or harming patients in a particular risk group). Ideally the range of individual risk estimates within a risk group would be narrow, making it easier to apply the risk group's average probability of dying to individuals within the group.

If a study couldn't follow all subjects for the entire time period of interest, the varying follow-up times can still be used to estimate survival (or mortality) curves. Survival curves have time on the x-axis and the estimated cumulative proportion surviving on the y-axis. The median survival time is the time when a survival curve reaches 0.5 on the y-axis. The median survival time can also be used as a proxy for life expectancy (an average) because half of the group lived longer and half shorter than the median survival time. To estimate life expectancy, one would have to fit a parametric equation to the survival curve and extrapolate it to cover the period of interest or until the curve reaches zero (all people in the cohort are deceased).^4,5^ Cox proportional hazards regression models are often used to relate multiple predictor variables to the survival times. One can use a fitted Cox regression model to estimate the probability of surviving (or dying) at a specified time or to estimate a survival (or mortality) curve using a patient's values of the predictor variables.

A C-statistic is commonly reported to help evaluate the ability of a mortality prediction model to identify (discriminate) the patients who did or didn't die within the period of follow-up. It is a measure of concordance or correlation (hence, the name “C-statistic”) between observed and estimated of survival probabilities or times. Thus, C-statistics measure the ability of a model to rank patients according to their risk but do not assess the ability of a model to assign accurate probabilities of surviving or the model's calibration. A C-statistic equal to 0.5 indicates the model did not discriminate those who survived or died during the period of follow-up any better than flipping a coin.

If a model's calculated risks are categorized using a particular cut-off to predict whether a patient will or will not die within a specified period of time, then the sensitivity (the proportion of all deaths that had risk scores exceeding the cut-off), and the specificity (the proportion of survivors that had risk scores less than the cut-off) can be estimated for the cut-off. Whether any cut-offs have a sufficient sensitivity and/or specificity for clinicians to use needs to be determined. The likelihood of finding a cut-off that has both a high sensitivity and specificity increases as the value of the C-statistic approaches 1.0. Given a proposed cut-off for making prognostic predictions, the positive predictive value (the proportion of patients above the cut-off that would be predicted to die and do) and the negative predictive value (the proportion of patients below the cut-off that would be predicted to survive that do) can be estimated. Primary care providers may require a very high positive and/or negative predictive value – that is, few prediction errors – before they're willing to use a quantitative model to predict whether a patient will survive.

## KQ2 Of the life expectancy calculators being reviewed, have any external validation studies been published between 2011 and 2016? If yes, what population was studied and what was the predictive accuracy therein?

Validation refers to testing a prediction model in a new sample of patients that was not used to develop the model. Ideally, a mortality prediction model should be validated in the patient population in which it will be used or a very similar patient population. Often validation is done by randomly splitting a sample of patients into one or more subsamples and using one subsample to develop the model and another subsample to validate the model. However, this approach may be overly optimistic in regards to future predictive performance because the distributions of predictor variables and mortality tend to be similar in randomly split samples. Validation studies that used different patients and time periods were considered to be more informative.

Before validating the predictive accuracy in a new sample of patients, it is appropriate to check the calibration of the prediction model in the new sample and perhaps recalibrate it before examining the predictive performance. Some validation studies may simply re-estimate the regression coefficients for the predictor variables although this practice is discouraged because the new estimates may be less precise if the external validation sample is small and less generalizable than re-calibrated estimates.

## KQ3 What is the clinical use of the mortality prediction models (aka life expectancy calculators), and was there improvement in patient survival times, health-related quality of life, provider-patient communication, patient satisfaction and participation in clinical decisions, or lower healthcare utilization and costs?

To address this key question, we were particularly interested in finding randomized controlled trials that compared clinical use of a mortality prediction model to usual care without the prediction model.

### PICOTS

Population: Middle- to older-aged adults (age 45 years and older) that were not in a hospital at the start of follow-up. If the study included a younger adult age range, it was included especially if predictive accuracy was evaluated in a more elderly subgroup.

Intervention: Calculation of life expectancy (or a proxy) using predictor variables that are generally available for outpatients being seen by primary care providers. Less generalizable disease-specific mortality prediction models or those that incorporated disease-specific or novel predictor variables were excluded. Models that predicted inpatient mortality or used a number of inpatient-specific predictor variables that would only be available for hospitalized patients were also excluded. Models that incorporated inpatient diagnosis codes as well as outpatient diagnosis codes were included.

Comparator: None

Outcomes

KQ1, KQ2: Predictive accuracy in a validation sample. See text under KQ1 and KQ2 for a detailed explication.

KQ3: Clinical use of a prediction model, improvement in patients' survival times, health-related quality of life, provider-patient communication, patient satisfaction and participation in clinical decisions, and healthcare utilization and costs when prediction model was made available to primary care providers.

Timing: Any follow-up time period that may be pertinent to a clinical decision.

Setting: Outpatient primary care.