# DEFINITIONS

Term: Definition
Life expectancy: The estimated (calculated) average number of years a group of people is expected to live. Most individuals in the group will live longer or shorter than the average life expectancy.
Mortality Prediction Model: A statistical model that uses predictor variables to the estimate the probability (risk score) an individual will be alive or deceased at a specified future time.
Risk Groups: Groups formed by categorizing individual estimated probabilities of dying.
Survival (or mortality) curve: Graphical plot of the estimated cumulative probability of surviving (or dying) versus time. Cumulative probabilities are often reported as a percentage.
Median survival time: The time when the cumulative probability of survival (or death) reaches 0.50 (50%). May be used as a proxy for life expectancy because 50% of the people in a group are expected to live longer and 50% shorter than the estimated median survival time.
Validation: Testing a prediction model in a new sample of patients that was not used to develop the model. Often validation is done by randomly splitting a sample of patients into one or more subsamples and using one subsample to develop the model and the other subsample to validate the model. However, this approach may be overly optimistic in regards to future predictive performance because the distributions of predictor variables and mortality tend to be similar in randomly split samples.
Calibration: The difference in the predicted number of deaths as compared to the observed number in each risk group. If the differences are small, the model is well-calibrated to the studied sample.
C-statistic: A measure of how well the prediction model's risk scores discriminate individuals who did or did not die within a specified period of time. C-statistics indicate the ability of a prediction model to rank individuals in concordance with their observed survival times. A model with a C-statistic that's not much better than 0.5 will not predict who will live or die much better than flipping a coin. On the other hand, the closer the C-statistic is to 1.0, the more likely it is that the prediction model can be used to make accurate survival predictions with an acceptably low number of prediction errors.
Sensitivity: The proportion of all decedents during a period of time that had risk scores exceeding a threshold being used to predict death.
Specificity: The proportion of survivors during a period of time that had risk scores less than a threshold being used to predict survival.
Positive Predictive Value: Given a proposed risk score threshold for making prognostic predictions, the proportion of patients above the threshold that would be predicted to die within a specified period of time and do.
Negative Predictive Value: Given a proposed risk score threshold for making prognostic predictions, the proportion of patients below the threshold that would be predicted to survive for a specified period of time and do.