# APPENDIX C EVIDENCE TABLES

Table 1 Study Characteristics

Table 2 Model Characteristics and Performance