# APPENDIX B PEER REVIEW COMMENTS/AUTHOR RESPONSES

Question | Reviewer Comment | Author Response
Are the objectives, scope, and methods for this review clearly described? | Yes | Thank you
Are the objectives, scope, and methods for this review clearly described? | | Thank you
Are the objectives, scope, and methods for this review clearly described? | Yes | Thank you
Are the objectives, scope, and methods for this review clearly described? | | Thank you
Are the objectives, scope, and methods for this review clearly described? | Yes | Thank you
Is there any indication of bias in our synthesis of the evidence? | No | Thank you
Is there any indication of bias in our synthesis of the evidence? | | Thank you
Is there any indication of bias in our synthesis of the evidence? | No | Thank you
Is there any indication of bias in our synthesis of the evidence? | | Thank you
Is there any indication of bias in our synthesis of the evidence? | No | Thank you
Are there any [underlined: published] or [underlined: unpublished] studies that we may have overlooked? | No | No response needed
Are there any [underlined: published] or [underlined: unpublished] studies that we may have overlooked?
Are there any [underlined: published] or [underlined: unpublished] studies that we may have overlooked? | Yes -1. Cruz et al JAMA research letter 2012 Predicting 10 year mortality in older adults. Granted, a research letter not a full research publication, but a high impact journal and an important update to the prior 4 year mortality index. 2. Lee et al PLOS one 2014 Individualizing life expectancy estimates using Gompertz… The conclusion of the report discuss lack of prognostic models that estimate life expectancy (time to death) rather than mortality risk (risk of death over a given time frame). This study estimates life expectancy, using the Lee index mentioned in 1 above. 3. Schonberg M JAGS 2011 External Validation of an index to predict 9 year…Granted, included in our review by Yourman, published in 2011 so I believe should have been included. | We have reviewed the suggested studies. Although the Cruz and Schoenborn prognostic models are potentially useful, these reports were not included in this review because the mortality prediction models are based on self-reported national survey data and would require similar patient questionnaires be administered by primary care clinics. We have included the Lee et al 2014 reference so readers can see how one could model survival curves to estimate life expectancy.
Are there any [underlined: published] or [underlined: unpublished] studies that we may have overlooked?
Are there any [underlined: published] or [underlined: unpublished] studies that we may have overlooked? | No | No response needed
Additional suggestions or comments can be provided below. If applicable, please indicate the page and line numbers from the draft report. | p. 5 line 5 - should be “insubstantial” rather than “unsubstantial” p. 5 line 10 - “quasi-validation” should probably be defined in the table on p 1 (or avoided altogether as an imprecise term). | We have made the suggested change on pg 5, line 5. ‘Quasi’ simply means the studies were not true external validation studies, however they were in a sense validation studies. We have pointed that none of the studies reviewed for KQ2 were true validation studies, and dropped ‘quasi’ from the Table title. We did not feel a need to define quasi in the table on page 1.
Additional suggestions or comments can be provided below. If applicable, please indicate the page and line numbers from the draft report.
Additional suggestions or comments can be provided below. If applicable, please indicate the page and line numbers from the draft report. | Major points:
Additional suggestions or comments can be provided below. If applicable, please indicate the page and line numbers from the draft report. | 1. As senior author of the Yourman systematic review of prognostic indices for older adults, I'm pleased that this report has been commissioned and well executed. Many of the conclusions remain the same - people just are not studying the use/usefulness of prognostic indices in clinical practice. As a key member of the eprognosis team, a free website dedicated to making prognostic models available to clinicians, I can testify that prognostic models are being used in everyday practice. Clinicians come up to me all the time, from all over the country, and say “I use eprognosis.” It seems to be more the specialists that use the models rather than the primary care clinicians, as a recent study by Nancy Shoenborn in JAMA Internal Medicine 2016 suggests. | The Schoenborn article is now mentioned in the Introduction of the Evidence Report to support an important statement that providers often don't share long-term prognostic assessments with their patients in part due to their uncertainty.
Additional suggestions or comments can be provided below. If applicable, please indicate the page and line numbers from the draft report. | 2. The conclusions are based on the time limited update between 2011 and 2016. Yet the underlying question “are there clinically useful prognostic models for VA primary care patients” need not be restricted to this time frame. Certainly, risk may change with time. But have things changed that much between, say 2000, and 2016? My guess is no, the same factors that put persons at risk in 2000 are likely to put persons at risk in 2016. Age, gender, functional limitations. We haven't cured cancer. To really address the underlying question, the VA will need to consider the accuracy and pragmatic usefulness of prior studies not included in this report. | We agree. The VA can refer to these previous reviews, thus we focused on more recent studies.
Additional suggestions or comments can be provided below. If applicable, please indicate the page and line numbers from the draft report. | 3. Why no mention of the CAN score? This is the giant elephant in the room that VA researchers are talking about. Apparently it's calculated for veterans and hard but possible to access in the medical record. What's the evidence? How useful is it? Omission is a major limitation as it will be the first thing on many VA clinician/researcher's minds when they think VA data and prognostic index. | We had not pointed out that the 2 Wang articles cited for KQ1 and KQ2 represent the VA Care Assessment Needs (CAN) model. We have now repeatedly made this connection in the text and table footnotes.
Additional suggestions or comments can be provided below. If applicable, please indicate the page and line numbers from the draft report. | 4. Minor points; - Explain what a “quasi-validation” study means.; - The two studies by Austin seem to really be one study. This question comes up immediately as all data in the tables about them are essentially identical. One shouldn't have to wait for a footnote to discover one study is simply developing a point score system using the same model. Not clear if this requires a separate citation and line in the table, as it's the same index. Might be better organized if by index rather than by publication. | ‘Quasi’ is used to indicate the studies were not true external validation studies, however they were in a sense validation studies. We have pointed that none of the studies reviewed for KQ2 were true validation studies, and dropped ‘quasi’ from the Table title. We did not feel a need to define quasi in the table on page 1.
Additional suggestions or comments can be provided below. If applicable, please indicate the page and line numbers from the draft report.
Additional suggestions or comments can be provided below. If applicable, please indicate the page and line numbers from the draft report. | Thank you for the opportunity to review this excellent ESP. The authors sought to review recent life expectancy calculators for use in primary care practice. In particular, they looked for new calculators published since 2011, external validations of those new calculators, and clinical applications of the calculators. Their research questions were specific, their methods were clear, and the document is well written. Their primary findings are also clear. There have been multiple calculators created, including one in VA. These calculators have had quite good testing characteristics generally, but have not been validated in external samples and have not had any study in clinical practice. The tables and figures were clear and will be a valuable summary for anyone doing this type of work. Their findings drive home what I think will be a central issue in health services and implementation science for the next decade or more. This is that Big Data will make risk prediction reasonably easy and accurate, but having prediction tools does not tell us what predictions are useful, how do we use them, and how do we integrate tools into the system to be useful to patients, providers, and healthcare leaders. These questions will likely be very important, but they've shown few people seem to be asking them. | Thank you.
Additional suggestions or comments can be provided below. If applicable, please indicate the page and line numbers from the draft report. | At the broadest level, I feel like the questions were very well formulated, but the underlying problems the questions were trying to solve were somewhat less so. Exactly how is this information going to be used inside or outside VA? If this question were answered more explicitly, some of their other choices may have been slightly different. For example, they found a good study by Wang (the senior author of which is an operational partner on this project) that used VA data. If VA wants to implement a life expectancy calculator, shouldn't they just use this tool? Are there things other tools did that a modified VA-based tool would want to do? For KQ2 and KQ3, they were unlikely to find validation studies since the studies included were already recent. Here they could have also used any study in Yourman's 2011 JAMA paper, which was one of the inspirations for this study. The team that wrote the JAMA paper has a website, eprognosis.org, that does some of the things that KQ3 wanted to address, though I don't know if they have validated it in any way. While adding older studies may have been reasonably out of scope for this project, it could have found some interesting information. | As pointed out in the text, the current VA model known as the CAN score doesn't predict all-cause model and wasn't developed to estimate life expectancy or evaluated as such, but could be adapted to do so.
Additional suggestions or comments can be provided below. If applicable, please indicate the page and line numbers from the draft report. | Their search strategy was reasonable. They only used Medline, which can miss citations. Because this is not a meta-analysis, missing citations is not a terribly big deal, so I find this reasonable. While I know this isn't the primary point of an ESP, I do wish the authors expanded their interpretive Research Gaps section a little. I was curious what they felt about each of the different scores, how they differ, and what future developers or users could learn from them. | If an effort to guide the VA, we tried to focus on what the good performing models had in common, and what further evaluation would be needed to support their use.
Additional suggestions or comments can be provided below. If applicable, please indicate the page and line numbers from the draft report. | A few small typos P8 “appropriate to to” P12 Moons2014 should be inside the period. | The P8 typo has been corrected and all references have been converted to superscript format.