# APPENDIX A SEARCH STRATEGY

MEDLINE (Ovid) through May 2016

1. (life adj expectancy).m_titl.
2. (survival or mortality or death).m_titl.
3. 1 or 2
4. (calculat$ or instrument$ or index or indice$ or model$ or tool$ or prognosis or risk or predict$ or estimat$).m_titl.
5. 3 and 4
6. (valid$ or calibrat$ or compar$).mp. [mp=title, abstract, original title, name of substance word, subject heading word, keyword heading word, protocol supplementary concept word, rare disease supplementary concept word, unique identifier]
7. 5 and 6
8. limit 5 to (english language and humans and yr=“2011 -Current” and (“middle-aged (45 plus years)” or “all aged (65 and over)” or “aged (80 and over)”))
9. limit 7 to (english language and humans and yr=“2011 -Current” and (“middle-aged (45 plus years)” or “all aged (65 and over)” or “aged (80 and over)”))
10. limit 8 to (clinical trial or comparative study or controlled clinical trial or evaluation studies or meta analysis or observational study or pragmatic clinical trial or randomized controlled trial or systematic reviews or validation studies)
11. limit 9 to (clinical trial or comparative study or controlled clinical trial or evaluation studies or meta analysis or observational study or pragmatic clinical trial or randomized controlled trial or systematic reviews or validation studies)
12. 8 NOT 9