# SUMMARY AND DISCUSSION

Interest in mechanical exclusion of the LAA to reduce the risk of stroke in patients with atrial fibrillation has grown rapidly in recent years. We systematically reviewed the literature and found 12 studies assessing the benefits and harms of percutaneous approaches to LAA exclusion, and 7 studies assessing the benefits and harms of surgical LAA exclusion. Overall, there is limited evidence that one specific approach to percutaneous LAA exclusion may be an effective alternative to long-term oral anticoagulation in selected patients who are closely followed and in whom procedural success is sustained, though there are significant procedure-related harms. There is insufficient evidence to assess the benefits of surgical LAA exclusion, though these procedures do not appear to be associated with a significant increase in harms over the heart surgery during which the procedures are typically performed (Table 7).

Table 7 Summary of the evidence on percutaneous and surgical interventions to occlude or remove the LAA

Outcome | Device or procedure N studies (N=combined participants) | Findings | Strength of Evidence^*^ | Comments
Percutaneous interventions
Mortality | Watchman 2 RCTs (N=1,114) | No significant difference in mortality. RR (95% CI) in 2 RCTs: 1.20 (0.31 to 4.56) 0.62 (0.34 to 1.24) | Low | Limited applicability: only one device has been studied in 2 RCTs. Patients were eligible to receive LT-OAC. Low precision (wide confidence intervals).
Stroke | Watchman 2 RCTs (N=1,114) | No significant difference in risk of stroke. RR (95% CI): in 2 RCTs: 0.71 (0.35 to 1.64) 3.28 (0.37 to 25.31) | Low | Limited applicability: only one device has been studied in 2 RCTs. Patients were eligible to receive LT-OAC. Low precision (wide confidence intervals).
Harms | ACP: 3 registries (N=147) Coherex: 1 registry (N=4) Lariat: 2 registries (N=93) PLAATO: 5 registries (N=441) Watchman: 2 RCTs + 4 registries (N=742) Device not specified: 2 registries (N=211) | Serious procedure- or device-related safety events (% of patients): 1.6 to 13.6 Overall, rate of serious adverse events within 7 days of device implantation was 6.5% (98/1506). | Moderate | Various devices were examined among 2 trials and 11 observational studies. Wide range of event rates across studies and relatively small number of patients treated in each observational study limited strength of findings.
Surgical interventions
Mortality | Sutures or stapler in 3 RCTs (N=171) Various excision and exclusion techniques in 4 Cohort studies (N=1695) | No significant difference in mortality, among studies in which at least one event occurred in both groups: In 1 RCT: 7.7 vs 12% (P > .05) RR (95% CI) 0.64 (0.12, 3.52) In 1 cohort: 5.0 vs 8.4% (P > .05) RR (95% CI) 0.60 (0.22 to 1.60) | Insufficient | Trials too small and event rates too low to determine effectiveness of procedure.
Stroke | 3 RCTs (N=171) 2 cohort studies (N=1500) | No significant difference in risk of stroke, among studies where at least one event occurred in both groups: In 1 RCT: 3.8 vs 12% (P > .05); RR (95% CI) 0.32 (0.03 to 2.88) In 2 cohorts: 1.0 vs 1.4% (P = .44) 0.84 vs 1.7% (P > .05) | Insufficient | Trials too small and event rates too low to determine effectiveness of procedure.
Harms | 3 RCTs (N=171) 1 cohort study (N=238) | Serious safety events: 6.9-32.0% of patients No significant differences in most major harms between cardiac surgery groups with and without LAA exclusion | Low | Limited number of studies and limited number of patients included.

* The overall quality of evidence for each outcome is based on the consistency, coherence, and applicability of the body of evidence, as well as the internal validity of individual studies. The strength of evidence is classified as follows:11

- High = Further research is very unlikely to change our confidence on the estimate of effect.
- Moderate = Further research is likely to have an important impact on our confidence in the estimate of effect and may change the estimate.
- Low = Further research is very likely to have an important impact on our confidence in the estimate of effect and is likely to change the estimate.
- Insufficient = Any estimate of effect is very uncertain.

Our findings corroborate and add to several recent systematic reviews,36-39 A recently published patient-level meta-analysis40 similarly found no significant difference in risk of stroke between percutaneous LAA exclusion using the Watchman device and long-term warfarin therapy (HR 1.02, 95% CI 0.62 to 1.7).40 In contrast to prior reviews we examined both percutaneous and surgical approaches to LAA exclusion. Also, we systematically examined both trial and observational study data.

## Percutaneous LAA exclusion

There is low-strength evidence that percutaneous LAA exclusion with the Watchman device is associated with a similar risk of long-term stroke and mortality as continued oral anticoagulation therapy. Most patients who received the Watchman device were able to discontinue oral anticoagulant therapy after undergoing a follow-up TEE showing persistent closure of the LAA at 3-6 months. However, there is moderate-strength evidence that a substantial proportion of patients experienced serious periprocedural harms. There is insufficient evidence to determine whether factors such as operator experience, patient selection criteria, or choice of device can modify these risks.

There are several clinical situations in which percutaneous LAA exclusion may be a potentially attractive option, though the data directly supporting use in these circumstances is limited. First, LAA exclusion might be especially attractive for patients unable to take oral anticoagulants. However, the trial data most closely apply to patients who do not have contraindications to long-term oral anticoagulant therapy. In these trials, warfarin was used typically for 3-6 months until device endothelialization and LAA closure was achieved.

A number of observational studies included patients ineligible for long-term oral anticoagulant therapy,19-22,24,25 and while most found low rates of stroke over 1-2 years of follow-up, at least one study found higher incidence of stroke over a longer follow-up period.20 Of note, even though warfarin was not used, patients in most of these studies used dual antiplatelet therapy for a duration ranging from 4 weeks to 6 months. Dual antiplatelet therapy (DAPT) in the population of patients with atrial fibrillation who have increased risk of stroke and for whom vitamin-K antagonists are unsuitable is associated with a 2.0% risk of major bleeding annually.41 It is notable that in a large study of warfarin versus DAPT for prevention of stroke in AF the risk of major bleeding was similar between groups (respectively 2.21% annual risk of stroke vs 2.42%, RR 1.10, 95% CI 0.83-1.45, P = .53). Minor bleeding and overall bleeding was increased in patients taking DAPT compared to warfarin (15.4% risk per year vs 13.2%, RR 1.21, 95% CI 1.08-1.35, P = .001).42 Thus as long as the protocol for the use of LAA closure devices includes DAPT for any significant length of time it may not be an attractive option for patients who are high risk for bleeding complications and who do not wish to take, or have contraindications to, warfarin.

The clinical circumstances which contribute to anticoagulant ineligibility could also contribute to one's risk of suffering a periprocedural harm. While we do not have data to directly compare rates of periprocedural harms in patients eligible and ineligible for anticoagulant therapy, up to 8.7% of patients experienced a serious periprocedural safety event among 8 observational studies in patients ineligible for oral anticoagulant therapy.17,19-22,24,25,28

The second clinical circumstance in which LAA exclusion might provide a useful alternative is for patients who might otherwise accrue a more substantial bleeding risk from oral anticoagulant therapy over longer time horizons. Take, for example, a 70 year-old woman with a history of atrial fibrillation, hypertension, and a prior stroke who is living independently and is a candidate for OAC. She has an annual stroke risk of 6.7% (based on CHADS2-VASC = 5)1 and would be expected to have a significant benefit from OAC. This same patient would be considered at high risk of major bleed (HAS-BLED = 3) with an expected 3.7 bleeds per 100 patient-years of follow-up while on OAC.43 She will experience these annual risks of bleeding for the duration of her OAC therapy. In the PROTECT-AF trial, most events in the LAA exclusion group accrued earlier on in the study, while event rates in the control group increased steadily (though remained lower overall) over 3 years of follow-up.14 Theoretically, then, it is possible that the risks of long-term anticoagulation might eventually offset the near-term risks of LAA exclusion device placement. However, this has not been tested empirically and, given that not all cardioembolic strokes in atrial fibrillation originate in the left atrial appendage, it is certainly possible that long-term stroke risk in patients receiving a device who remain off anticoagulation may increase.

Third, some patients may simply prefer the placement of an LAA exclusion device over the inconvenience of long-term OAC. Policy makers will need to consider whether routine availability of periprocedural LAA exclusion for preference-sensitive indications is warranted.

There are a variety of devices being used for LAA exclusion, but there is not adequate evidence that the efficacy and safety of each of these devices is similar enough to comfortably extrapolate data from one device and apply to the use of a different device. While the techniques used for many of the devices are similar, there are still important differences, perhaps most notably for the Lariat device which takes an epicardial approach to snaring and externally excluding the LAA. For the time being, the evidence for device efficacy applies most closely to the Watchman device and there is insufficient evidence to determine the efficacy of other devices.

There is enough variation in the reported safety of percutaneous exclusion devices that, if the VHA does choose to pursue more widespread use of LAA exclusion procedures, an outcomes registry carefully tracking periprocedural and longer term harms should be established first, with results reviewed at periodic intervals. The finding that the multicenter observational studies often reported fairly high rates of serious periprocedural harms is troubling though the reasons for this finding are not clear. It is possible that patient selection may be less restrictive and operator experience more variable with broader adoption of a procedure.

Finally, it should be noted that the decision to discontinue anticoagulant therapy in the included studies was based on demonstrated LAA closure on follow-up TEE. Up to 4-6% of patients had continued evidence of LAA blood flow at 6 months, and this may be an underestimate as these figures do not account for the proportion of patients in trials and observational studies who refused follow-up TEE. The benefits and harms of percutaneous LAA exclusion in patients for whom TEE monitoring is infeasible remain essentially unknown.

## Surgical LAA exclusion

We found insufficient evidence to determine the efficacy of surgical LAA exclusion in reducing stroke. We found low strength evidence that surgical LAA exclusion in the context of heart surgery performed for another indication is unlikely to be associated with significant incremental harm.

While surgical LAA exclusion might seem analogous to performing an appendectomy during an exploratory laparotomy, the clinical implications may be quite different. The promise of surgical LAA exclusion is to reduce long-term risk of stroke and, possibly, to obviate the need for long-term oral anticoagulant therapy. However, we do not have sufficient evidence to determine whether prophylactic surgical LAA exclusion actually does reduce stroke. In the meantime, there is at least the theoretic possibility that surgical LAA exclusion may offer false reassurance to patients who then decide to discontinue oral anticoagulant therapy.

Limited data from one trial and one observational study suggest that a relatively high proportion of patients have persistent LAA blood flow detected on follow-up TEE.30,34 Given the lack of robust efficacy data, and the relatively low rates of long-term procedural success, patients who do undergo LAA exclusion during heart surgery should likely not discontinue long-term oral anticoagulant therapy.

## LIMITATIONS

While we adhered to published standards for systematic review conduct, there are several potential methodologic limitations to note. First, we excluded non-English language studies. There is empiric data, however, suggesting that reviews restricted to English-language studies are largely concordant with reviews without language restrictions.44 Second, we excluded observational studies enrolling fewer than 50 participants. However, we felt that these typically single-center studies with very small denominators were unlikely to yield reliable information about rates of harms or procedural success.

There are significant limitations in this body of evidence as a whole, and these are noted throughout our report. Clearly, one of the biggest limitations is simply the relative paucity of methodologically rigorous studies examining the efficacy of percutaneous and surgical LAA exclusion.

## RESEARCH GAPS/FUTURE RESEARCH

Trials of percutaneous LAA interventions were limited to studies of the Watchman device in patients who were eligible for long-term warfarin therapy. Trials of surgical LAA interventions were few and limited by sample size. Several studies that should add substantively to this body of evidence are underway (Table 8), including a large RCT of surgical interventions with an estimated sample size of 4,700 patients; studies of recently developed percutaneous devices (LAmbre and Occlutech); and a trial comparing Watchman with Apixaban in patients ineligible for warfarin therapy.

Table 8 Ongoing studies of percutaneous and surgical LAA interventions

Study title; Clinicaltrials.gov ID | Device or technique vs control | Study design; Estimated enrollment; Status; Estimated completion date | Country; Funding source | Comment
Percutaneous interventions
Feasibility and Safety Study of LAmbre Left Atrial Appendage Occluder; NCT01920412 | LAmbre | Single-group, open-label N=20 Recruiting as of Aug 2013; Est. completion: Sept 2014 | China; Lifetech Scientific (Shenzhen) Co., Ltd. | First-in-man study
Safety and Efficacy Study of LAmbre LAA Closure Device for Treating AF Patients Who Cannot Take Warfarin; NCT02029014 | LAmbre | Single group, open-label N=154 Recruiting as of Mar 2014; Est. completion: Jul 2016 | China; Lifetech Scientific (Shenzhen) Co., Ltd. | Includes patients who cannot be treated long-term with Warfarin
Prospective, Non-randomized, Safety and Efficacy Study of a New Occluder Design for Minimally Invasive Closure of the Left Atrial Appendage (LAA) in Patients With Atrial Fibrillation (OLAAC); NCT02105584 | Occlutech | Single group, open-label N=105 Recruiting as of Apr 2014; Est. completion: Apr 2016 | Germany Occlutech International AB | Includes patients eligible or non-eligible for long-term oral anticoagulation therapy
Left Atrial Appendage Closure vs Novel Anticoagulation Agents in Atrial Fibrillation (PRAGUE-17); NCT02426944 | Watchman vs Apixaban | RCT, open-label N=400 Ongoing not recruiting as of April 2015; Est. completion: May 2020 | Czech Republic; Charles University and Ministry of Health | Includes patients with significant bleeding during warfarin treatment
Surgical interventions
Left Atrial Appendage Occlusion Study III (LAAOS III); NCT01561651 | Cardiac surgery with vs without LAA occlusion via suture and/or surgical stapler | RCT, double-blinded N=4700 Recruiting as of May 2014; Est. completion: May 2019 | Canada; Population Health Research Institute | Estimated mean follow-up of 4 years
Left Atrial Appendage CLOSURE for the Prevention of Thromboembolisms in Patients Undergoing Aortic Bioprosthesis Surgery (LAA-CLOSURE); NCT02321137 | Valve surgery with vs without surgical LAA closure | RCT, open-label N=1040 Recruiting as of Dec 2014; Est. completion: Dec 2027 | Finland and Netherlands; 5 regional/university hospitals | Includes patients with no indication for long-term anticoagulation

## CONCLUSIONS

Overall, there is limited evidence that percutaneous LAA exclusion may be an effective alternative to long-term oral anticoagulation in selected patients who are closely followed and in whom procedural success is sustained. However, only one percutaneous device has been studied rigorously in trials, and percutaneous LAA exclusion has been associated with high rates of serious procedure-related harms in many studies. There is insufficient evidence to assess the benefits of surgical LAA exclusion. While surgical LAA exclusion does not appear to be associated with a significant increase in harms over the heart surgery during which the procedures are typically performed, rates of procedural success may be low. Overall, there is insufficient evidence to support the routine use of surgical LAA exclusion to reduce stroke risk or future need for anticoagulant therapy. There are a number of ongoing studies that should add substantively to this body of evidence over the next several years.