# RESULTS

We reviewed 2,566 titles and abstracts, including 2,469 from the electronic search and an additional 98 from reviewing reference lists and performing manual searches for recently published and unpublished or ongoing studies. After applying inclusion/exclusion criteria at the abstract level, we reviewed 207 full-text articles from which we found 20 primary studies that met our inclusion criteria. We also identified 5 systematic reviews of the effectiveness of percutaneous LAA devices. We contacted 7 device companies to request information about unpublished studies but received no response (Appendix D).

## LITERATURE FLOW

The diagram on the following page shows the yield of citations from database searches and other sources, the numbers of excluded abstracts and full-text articles, and the final yield of included studies (Figure 1).

Figure 1 Literature flow diagram

## PERCUTANEOUS LAA INTERVENTIONS

### KQ1 What is the effectiveness of LAA exclusion interventions compared with usual care?

We found 2 randomized controlled trials (RCTs) with low risk of bias, both of which compared the Watchman(R) Left Atrial Appendage Closure Device (Atritech, Inc., North Plymouth, MN, USA) to medical therapy with warfarin (Table 3). Inclusion into the PROTECT-AF12-14 trial required subjects to have non-valvular atrial fibrillation (NVAF) and a CHADS2^15^ score of at least 1, while the PREVAIL16 trial enrolled subjects with higher risk of stroke; patients were excluded from these trials if they had contraindication to warfarin therapy, recent stroke, or a patent foramen ovale/atrial septal defect.

Table 3 Health outcomes, adverse effects, and procedural success in trials comparing percutaneous LAAO to warfarin therapy

Study, Setting, Mean follow-up time | Patient characteristics, T vs C | KQ1. Health outcome effects, T vs C | KQ2. Harms associated with LAA exclusion, T vs C | KQ4. Rates of procedural success, T vs C
PREVAIL16 50 sites, USA 11.8 months | N patients: 269 vs 138 Mean age: 74.0 vs 74.9 Male %: 67.7 vs 74.6 CHADS2 mean: 2.6 vs 2.6 CHA2DS2-VASc mean: 3.8 vs 3.9 AF %: 100 vs 100 Stroke %: 27.5 vs 28.3 CHF %: 23.4 vs 23.2 HTN %: 88.5 vs 97.1 (P = .003) DM %: 33.8 vs 29.7 | Ischemic stroke: 5 of 269 (1.9%) vs 1 of 138 (0.7%) Hemorrhagic stroke: 1 of 269 (0.4%) vs 0 of 138 (0.0%) Death (cardiovascular/unexplained): 7 of 269 (2.6%) vs 3 of 138 (2.2%) Systemic embolism: 1 of 269 (0.4%) vs 0 of 138 (0.0%) | Total serious AEs: 11 (4.1%) of 269^**^ Device embolization: 2 of 269 (0.7%) Arteriovenous fistula: 1 of 269 (0.4%) Cardiac perforation: 1 of 269 (0.4%) Pericardial effusion requiring surgery: 1 of 269 (0.4%) Pericardial effusion with pericardiocentesis: 4 of 269 (1.5%) Major bleed requiring transfusion: 1 of 269 (0.4%) Procedure-related stroke: 1 of 269 (0.4%) | 252 (95.1%) successfully implanted of 265 attempted. Discontinuation of warfarin^*^, among N assessed by TEE: 227 (92.2%) of 246 at 45 days 235 (98.3%) of 239 at 6 months 141 (99.3%) of 142 at 12 months
PROTECT AF12-14 59 sites USA, Europe 12 months | N patients: 463 vs 244 Mean age: 71.7 vs 72.9 Male %: 70.4 vs 70.1 Mean CHADS: 2.2 vs 2.4 (P = .0517) AF %: 100 vs 100 Stroke/TIA %: 17.7 vs 20.1 CAD %: 39.6 vs 49.5 (P = .0275) CHF %: 26.8 vs 27.0 HTN %: 90.9 vs 90.3 DM %: 24.9 vs 30.6 | Ischemic stroke: 15 of 463 (3.0%) vs 6 of 244 (2.5%) Cardiovascular/unexplained death: 5 of 463 (1.1%) vs 10 of 244 (4.1%), P <.05 Hemorrhagic stroke: 1 of 463 (0.2%) vs 6 of 244 (2.5%) Systemic embolism: 2 of 463 (0.4%) vs 0 of 244 (0%) All strokes: 16 of 463 (3.4%) vs 12 of 244 (4.9%) All-cause mortality: 21 of 463 (4.5%) vs 18 of 244 (7.4%) Quality of Life (QoL) assessed by Short-Form 12 vs 2, Mean change from baseline to 12 months: Total physical score: +0.4 vs -0.2, P = .0015 Total mental score: 0.0 vs -0.9, P = .6400 Physical functioning: +0.1 vs -3.0, P = .0005 Physical role limitation: +0.4 vs -2.35, P = .0021 Pain: -0.1 vs -1.0, P = .5668 General health: +0.8 vs -0.2, P = .0606 Vitality: +0.2 vs -1.4, P = .1614 Social functioning: +0.5 vs -1.6, P = .0650 Emotional role limitation: -0.3 vs -1.8, P = .1115 Mental health: 0.0 vs -0.9, P = .6780 | Total serious AEs: 49 (10.5%) of 463 vs 20 (8.2%) of 244 Pericardial effusion requiring surgery: 15 of 463 (3.2%) Pericardial effusion with pericardiocentesis: 7 of 463 (1.5%) Device embolization: 3 of 463 (0.6%) Major bleeding: 16 of 463 (3.4%) Procedure-related stroke: 6 of 463 (1.1%) Other: 2 of 463 (0.4%) 27 (55%) of 49 primary safety events occurred on the day of the procedure. Timing of specific AEs not otherwise stated. | 408 (91%) successfully implanted of 449 attempted. Discontinuation of warfarin^*^, among N assessed by TEE: At 45 days: 348 (86%) of 401. 30 (7.5%) of 401 continued warfarin due to continued shunt At 6 months: 355 (92%) of 385. 14 (3.6%) of 385 continued warfarin due to continued shunt Control arm was within therapeutic INR range 66% of the time.

* Implies complete closure or residual peri-device flow <5mm in width on TEE.

** Total serious AEs in our report differs from primary source as we included procedure related strokes and pericardial effusions requiring any intervention.

The PROTECT-AF trial included 463 intervention and 244 control patients with non-valvular atrial fibrillation, and excluded patients with low stroke risk (CHADS2 of 0). The device was successfully deployed in 88% (408/463) of patients, though it was not attempted in 14 patients. Successful closure was obtained in 86% (348/401) of patients at 45 days and in 92% (355/385) at 6 months. Warfarin was typically discontinued with complete closure or if residual peri-device flow was less than 5 mm width on surveillance transesophageal echocardiogram (TEE). At 6 months, successful closure was demonstrated in 92% (355/385), although 5.6% (23/408) refused follow-up TEE. Most patients were able to stop warfarin therapy (7.5% (30/401), 3.6% (14/385), and 2.7% (10/370) of subjects in the LAA exclusion group remained on warfarin therapy at 45 days, 6 months, and 2 years respectively.13,14 The control arm was within therapeutic international normalized ratio (INR) range 66% of the time.

There was no difference in a composite primary efficacy endpoint including ischemic/hemorrhagic stroke, cardiovascular/unexplained death, and systemic embolism with 3.0 (1.9 to 4.5) events per 100 patient-years in the LAA exclusion group versus 4.9 (2.8 to 7.1) events per 100 patient-years in the warfarin group (rate ratio 0.62, 0.35 to 1.25). Cumulative events at 2.3 years mean follow up (standard deviation 1.1 years, median 2.4, range 0.5 to 9 years) were also similar with 3.0 (2.15 to 4.3) events per year in the LAA exclusion group versus 4.3 (2.6 to 5.9) events per year in the warfarin group. Overall, there was >99.9% posterior probability for non-inferiority for the LAA exclusion group compared to the warfarin treated group.13,14 Additionally, there was no statistically significant difference in mortality between the 2 groups.

In a subset of patients in the PROTECT-AF trial, quality of life on some subscales was modestly improved in the intervention group. However, the absolute differences were small and the findings subject to bias given lack of patient blinding and differential rates of follow-up in each group.12

The PREVAIL trial enrolled 407 subjects (269 assigned to LAA exclusion and 138 assigned to warfarin therapy) and followed them for an average of 11.8 months (standard deviation 5.8 months, median 12 months, range 0.03 to 25.9 months).16 Patients were slightly older and had a higher risk of stroke than the population included in the PROTECT-AF trial. Device deployment was successful in 95.1% (252/269) patients. At 6 months, device closure was demonstrated in 98.3% (235/239), though 11.2% (30/269) refused follow-up TEE.

The PREVAIL trial did not meet its target of non-inferiority for overall efficacy, although event rates were low and numerically comparable for both arms. Overall mortality was 2.6% in the LAA exclusion group versus 2.2% in the warfarin group. A composite outcome of death, ischemic/hemorrhagic stroke, or systemic embolism occurred in 5.2% of the LAA exclusion group and 2.9% of the warfarin group. On the other hand, the rate of events adjusted for person-time of observation months was similar: 18 month rate ratio of composite events was 1.07 (credible interval 0.57 to 1.89).16 The discrepancy in the reported results may be related to a later occurrence of outcomes in the device group.

### KQ2 What are the harms associated with LAA exclusion?

We found 2 trials and 11 observational studies reporting harms data (Tables 3 and 4). Serious periprocedural adverse events were reported in 1.6-13.6% of patients. Overall, the rate of periprocedural harms occurring within 7 days of device placement was 6.5% (98/1506). The types of periprocedural events most commonly reported included pericardial effusions with and without associated tamponade, bleeding, device thrombus, and device embolization.

Table 4 Procedural success, harms, and long-term stroke risk in registry studies of percutaneous LAA exclusion

Study, Setting | Device; Mean follow-up; N patients; Eligible/ineligible for LT-OAC | Patient characteristics | Periprocedural harms occurring within 7 days | Longer-term harms | Procedural success: Deployment, N (%) of attempted Closure, N (%) of patients assessed by TEE
Bartus, 2013^17^ Poland | Lariat 1 year N=89 Ineligible for LT-OAC | Mean age: 62 Male %: 57 CHADS2 mean: 1.9 CHA2DS2-VASc mean: 2.8 HAS-BLED mean: 2.4 Stroke/TIA %: 25 CAD %: 4 CHF %: 12 HTN %: 94 DM %: 10 | Serious procedure- or device-related safety events: Pericarditis: 2 (2.4%) of 85 | Pericardial effusion: 1 (1.2%) of 85 At 3 months, sudden cardiac death: 1 (1.2%) of 85 At 6 months, hemorrhagic stroke: 1 (1.2%) of 85 At 1 year, lacunar stroke: 1 (1.2%) of 85 | Deployment: 85 (95.5%) of 89 Closure:: 1 day: 81 (95%) of 85 30 days: 81 (95%) of 85 90 days: 77 (95%) of 81 1 year: 64 (98%)of 65
Price, 2014^23^ 8 sites USA | Lariat 112 days, median N=154 No criteria for LT-OAC; 60% were using an OAC at baseline | Mean age: 72 Male %: 62 CHADS 2 mean: 2.8 Cha2DS2-VASc mean: 4.1 HAS-BLED mean: 3.2 CHF %: 34 Stroke/TIA %: 38 HTN %: 81 DM %: 36 | Serious procedure- or device-related safety events occurred in 21 (13.6%) of 154 Major bleed: 14 (9.1%) of 154 Cardiac tamponade: 7 (4.5%) of 154 | Thrombus formation: 4 (3%) of 134 with follow-up available | Deployment: 145 (94.2%) of 154 Closure at end of procedure: 133 (92%) of 145 Closure at follow-up: 50 (79%) of 63
Nietlispach, 2013^18^ Single center Switzerland | Nondedicated LAA occlusion devices (off-label use of Amplatzer PFO, ASD and VSD occluders), N=32 Amplatzer ACP, N=120 32 months Eligible for LT-OAC | Mean age 72 Male %: 69 Mean CHA2DS2-Vasc: 3.46 Mean HASBLED score: 2.46 Stroke %: 31 HTN %: 75 DM %: 23 | Serious procedure- or device-related safety events: 19 (12.5%) of 152 Cardiac tamponade: 4 (2.6%) of 152 Device embolizations: 6 (4.0%) of 152 Device dislocations: 3 (1.7%) of 179 Pericardial effusion: 2 (1.1%) of 179 Neurologic events (2 TIA and 1 minor stroke): 3 (2.0%) of 152 GI bleeding resulting in death: 1 (0.7%) of 152 | Embolization: 1 (0.7%) of 152 Bleeding: 13 (8.6%) of 152 4 were major bleeds (2.6%): 2 intracerebral bleeds 2 subdural hematoma Ischemic stroke: 1 (0.7%) | Deployment: 146 (96.0%) of 152 Closure at 3-6 months: 137 (93.8%) of 146
Bayard, 2010^28^ 18 centers Europe | PLAATO N=180 9.6 months Ineligible for LT-OAC | Mean age: 70 Male %: 66 Mean CHADS2 score: 3.1 CHF %: 42 Stroke/TIA %: 59 HTN %: 83 DM %: 29 | Serious procedure- or device-related safety events: 8 (4.9%) of 162 Cardiac tamponade: 6 (3.7%) of 162 Cardiac death, procedure related: 2 (1.2%) of 162 | Stroke (at 129 patient-years follow-up): 2.3% Cardiac death: 5 (3.1%) of 162 | Deployment: 162 (90%) of 180 Closure at 2 months: 126 (90%) of 140
Block, 2009^20^ USA | PLAATO 5 years N=64 Ineligible for LT-OAC | Mean age: 73 Male %: 60.9 CHADS2 score of 1, %: 23.4 CHADS2 score 2+, %: 76.6 CHF %: 44 Stroke/TIA %: 69 HTN %: 77 DM %: 23.4 | Serious procedure- or device-related safety events: 1 (1.6%) of 64 (cardiac tamponade requiring surgery) | Stroke: 8 of 64 (12.5%) | Deployment: 61 (95.3%) of 64 Closure immediately after procedure: 55 (98.2%) of 56 Closure at 1 month: 22 (100%) of 22
Park, 2009^19^ Single-center prospective registry, Germany | PLAATO 2 years N=73 Ineligible for LT-OAC | Age 72.7 Male %: 50.7 CHADS2 mean score: 2.52 Stroke: 34.2 CAD %: 53.4 HTN%: 94.4 DM %: 36.1 | Serious procedure- or device-related safety events: 4 (5.5%) of 73 Pericardial effusion: 1 (1.4%) of 73 Device embolization resulting in sudden cardiac death 1 (1.4%) of 73 Stroke: 1 (1.4%) of 73 Device instability, explanted by open-heart surgery to avoid device embolization: 1 (1.4%) of 73 | Stroke: 0 (0.0%) | Deployment: 71 (97.2%) of 73 Closure at 3-6 months: 52 (100%) of 52 18 patients refused follow-up TEE
Ostermayer, 2005^24^ Multisite: USA, Europe, Canada | PLAATO 9.8 months N=111 Ineligible for LT-OAC | Age >= 65 yrs: 84% Age >75 yrs: 35% Male %: NR Mean CHADS2: 2.5 Stroke/TIA: 38% CAD: 41% CHF or LVEF <40%: 39% HTN: 72% | Serious procedure- or device-related safety events occurred in 7 (6.3%) of 111 Respiratory failure: 1 (0.9%) of 111 Pericardial effusion: 2 (1.8%) of 111; only 1 required pericardiocentesis Cardiac Tamponade: 2 (1.8%) of 111; both had pericardiocentesis Hemothorax: 1 (0.9%) of 111 | Stroke: 2 of 111 (1.8%) | Deployment: 108 (97.3%) of 111 Closure at end of procedure: 86 (97.7%) of 88 1 month: 60 (100%) of 60 6 months: 49 (98.0%) of 50
Reddy, 2013^25^ Multisite Germany, Czech Republic, New York | Watchman 14.4 months N=150 Ineligible for LT-OAC | Age 72.5 Male %: 64 Mean CHADS2 score: 2.8 Mean CHAD2DS2-VASC score: 4.4 Stroke/TIA %: 40.7 CHF/reduced LVEF %: 28.7 Vascular disease %: 18 HTN %: 94.7 DM %: 32 | Serious procedure- or device-related safety events occurred in 13 (8.7%) of 150 Pericardial effusion (with/without tamponade): 5 (3.3%) of 150 Device embolization: 2 (1.3%) of 150 Device thrombus: 6 (1.0%) of 150 | Device thrombus with ischemic stroke, 341 days post-implant: 1 (0.7%) of 150 All-cause stroke or systemic embolism: 4 (2.7%) of 150 Ischemic stroke: 3 (2.0%) of 150 Hemorrhagic stroke: 1 (0.7%) of 150 | Deployment: 142 (94.7%) of 150 Closure NR
CAP Registry26,27 26 centers | Watchman 16 months N=566 Eligible for LT-OAC | Mean age: 74 Male %: 65.5 CHADS mean: 2.4 CHADS score 1 = 25% CHADS score 2+ = 76% Stroke/TIA; 30.6% CHF %: 18.9 HTN %: 88.3 DM %: 24.7 | Serious procedure/device-related safety AE: 17 (3.7%) of 460 Serious pericardial effusion: 10 of 460 (2.2%) Bleeding: 3 of 460 (0.7%) Respiratory failure: 2 of 460 (0.4%) | NR | Deployment: 437 (95.0%) of 460 Closure NR
Gafoor, 2014^21^ Single center Retrospective case review, single center Germany | Watchman, n=26 ACP, n=27 PLAATO, n=13 Lariat, n=4 Coherex, n=4 1 year Ineligible for LT-OAC | Mean age: 83.4 Male %: 53.3 Mean CHADS2 = 3.3 Mean CHA2DS-VASc = 5.2 Stroke %: 21.3 CAD %: 41.3 CHF %: 36 HTN %: 96 DM %: 22.7 | Serious procedure- or device-related safety events occurred in 3 of 74 (4.1%) TIA: 1 of 74 (1.3%) Femoral bleeding (access site): 1 of 74 (1.3%) Device thrombus (patient not on anticoagulation): 1 of 74 (1.3%) | Death due to renal failure: 1 (1.4%) of 74 Stroke: 1 (1.4%) of 74 | Deployment: 75 (100%) of 75 Closure at: 1 day: 68 (90.1% of 75 1 year: 97.4%, N with TEE not reported
Matsuo, 2014^22^ Single center Germany | Watchman® or Amplatzer Cardiac Plug (ACP®) device) 6 months N=179 Ineligible for LT-OAC | Mean age 72.7 Male %: 58.7 Mean CHADS2 score = 2.9 Mean CHA2DS2VASC = 4.3 Mean HASBLED = 3.9 Prior stroke/TIA %: 27.9 CHF %: 39.1 Vascular disease %: 24.0 HTN %: 95.0 DM %: 44.7 | Serious procedure- or device-related safety events: 13 (7.3%) of 179 Cardiac tamponade: 2 (1.1%) Device dislocations: 3 (1.7%) Pericardial effusion: 2 (1.1%) Air embolization: 3 (1.7%) Device thrombus: 3 (1.7%) | Thrombus: 7 (4.2%) of 165 Among 145 with follow-up data at 6-months: Bleeding complications: 3 (2.0%) Upper GI bleeding: 2 (1.4%) Subdural hematoma: 1 (0.7%) Stroke: 0 (0.0%) | Deployment: Watchman: 163 (98.8%) of 165 ACP: 9 (90.0%) of 10 Closure at 45 days: 164 (99.4%) of 165 Discontinuation of OAC or Enoxaparine: 156 (94.5%) of 165

Abbreviations are found on page 5.

Two trials examined harms associated with placement of the Watchman device.13,16 In PROTECT-AF 10.6% (49/463) of patients experienced a safety event with 55.1% (27/49) of those occurring on the day of the procedure. Significant pericardial effusion followed by major bleeding accounted for most of these events. The authors note the rate of pericardial effusion declined with operator experience. In contrast, the safety event rate was much lower (2.2%) in the more recently conducted PREVAIL trial.16 Adverse event rates were similar in the single center17-22 and the multicenter studies.23-26

We did not find robust comparative effectiveness data to directly assess the relative rates of serious safety events according to the device used. However, there were serious periprocedural events including death or need for emergent surgery reported for all included devices.

Overall, patients had low rates of stroke and bleeding and there were no reported technical device failures over the long term. Data on longer-term safety from the observational studies is limited in part by either high rates of attrition24 or lack of information about the loss to follow-up.17,21,22,26,27 Additionally, the duration of follow-up ranged from 6 months to 5 years and there was no clear standard for which events were reported.

### KQ3a How do the benefits of LAA exclusion vary in different subgroups?

The evidence for use of LAA exclusion devices in different subgroups is limited to retrospective analysis of a single randomized controlled trial of the Watchman device. In PROTECT-AF the use of the Watchman appeared equally effective in men and women and was non-inferior to warfarin in patients with CHADS2 score greater than 1, patients who are greater than or equal to 75 years old, patients with normal and reduced left ventricular ejection fraction (LVEF), patients with prior stroke, and in those with higher CHADS2.^25^ Findings were also consistent in patients with paroxysmal and permanent atrial fibrillation.25 However, the strength of these findings should be considered low because of the post-hoc nature of these analyses and the relatively wide confidence intervals associated with the findings.

### KQ3b How do the harms of LAA exclusion vary in different subgroups?

The PROTECT-AF and PREVAIL trials of the Watchman device did not address harms in different subgroups.13,14,16 The observational studies did not directly compare rates of harms across patient subgroups. In these studies, there were a substantial proportion of older patients with higher stroke risk and the rates and types of periprocedural harms were similar across the studies.

While the 2 RCTs excluded patients who were ineligible to receive anticoagulant therapy, 7 of 11 observational studies included patients who were ineligible for long-term oral anticoagulant therapy. In most of these studies, the long-term rates of stroke were low – 2.1% (12/565) over the course of 6-24 months of follow-up.17,19,21,24,25 One study of the PLAATO device found a higher incidence of stroke (12.5%) during a follow-up period which lasted up to 5 years,20 though the annual rate of stroke is similar to studies with shorter follow-up periods. Long-term complications were not reported as part of the CAP Registry.26,27

### KQ4 What are the comparative effects of different techniques on health outcomes and rates of procedural success?

Given that RCT data is limited to a single device, the Watchman, and a single technique, it is impossible to compare the effectiveness of different techniques. The PREVAIL trial included analysis of the learning curve for implantation of the Watchman by requiring a minimum of 20% of participants from centers that had not previously participated in LAA exclusion trials with this device, as well as a requirement that a minimum of 25% of randomized patients be treated by new operators. The study found an overall implantation success of 95.1%., with no statistically significant difference in successful deployment when comparing experienced operators (96.3%) to new operators (93.2%; P = .256).16 Similarly, there were no significant differences in complication rates between experienced and new operators.

A number of different devices were represented among the observational studies; however, the Watchman and PLAATO devices were the most frequently studied. In these studies, the device was successfully deployed in most patients selected to undergo the procedure, regardless of the device used. In one study, device deployment rates were similar in the Watchman device (98.8%, 165 of 167) and the Amplatzer Cardiac Plug (ACP) device (90%, 9 of 10).22 Rates of device closure as determined by follow-up TEE were high among studies of different devices reporting this outcome, but there was substantial variation in the timing of follow-up, and a substantial proportion of patients did not undergo follow-up TEE.

## SURGICAL LAA INTERVENTIONS

### KQ1 What is the effectiveness of LAA exclusion interventions compared with usual care?

Three randomized controlled trials and 2 observational studies evaluated the effectiveness of surgical LAA exclusion compared with usual care (Table 5).

Table 5 Characteristics and findings of trials of cardiac surgery with vs without concomitant LAA occlusion or removal

Study, Setting, Surgery performed | Technique; length of follow-up | Sample size and patient characteristics, T vs C | KQ1. Health outcome effects, T vs C | KQ2. Harms associated with LAA exclusion, T vs C | KQ4. Rates of procedural success, T vs C
Healey, 2005^30^ Single site, Canada CABG | Sutures or stapler Mean 13 +/-7 months | N: 52 vs 25 Age, mean: 72 vs 71 Male %: 73 vs 72 History of AF %: 17 vs 8 Stroke %: 17 vs 0 HTN %: 75 vs 92 DM %: NR | Mortality: 0 vs 0 Postoperative AF: 12/52 vs 4/25 Intraoperative ischemic stroke: 1/52 vs 0/25 TIA: 1/52 vs 0/25 | Total serious AEs: 10 (19.2%) of 52 vs 1 (4%) of 25 Cross-clamp time (min): 72 vs 75 Intraoperative LAA tears: 8/52 vs 1/25 LAA tears in Tx group: Stapler: 4 Forceps: 2 Suture: 1 Not specified: 1 Perioperative stroke/TIA: 2 (2.6%) vs 0 | TEE at 8 weeks postop: 29/44 (66%) with occlusion defined as no flow beyond the line of occlusion and a residual stump of <1 cm. 8 patients refused follow-up TEE. % with complete occlusion at 8 weeks, suture vs stapler (P = .14): 5/11 (45%) vs 24/33 (72%) Complete occlusion, stapling device vs sutures alone (P = .14.): 24 (72%) of 33 vs 5 (45%) of 11
Nagpal, 2009^29^ Single center Italy Mitral valve surgery | Suture Postop period | N: 22 vs 21 Age, mean: 57.8 vs 59.2 Male %: 50 vs 57.1 AF %: 18.2 vs 19 TIA/stroke %: 0 vs 4.8 CAD %: 0 vs 0 DM %: 4.5 vs 0 | Mortality: 0/22 vs 0/21 Stroke: 0/22 vs 0/21 TIA: 1/22 vs 1/21 MI: 1/22 vs 0/21 | Total serious AEs: 7 (32%) of 22 vs 8 (38%) of 21 (P = .75) Mechanical ventilation time: 11.5 h vs 8 h (P = .078) Mean days in ICU: 2 vs 1 (P = .56) Composite of AEs (respiratory failure, IABP, renal dysfunction, PPM, sepsis, mediastinitis, re-op for bleeding): 5/22 vs 7/21 | NR
Whitlock, 2013^31^ 4 sites, Canada CABG and/or valve replacement | Sutures or stapler 30 days (in person); 1 year (telephone) | N: 26 vs 25 Age, mean: 77.4 v 74.6 Male %: 76.92 vs 76 AF %: 100 vs 100 CVA %: 23 vs 20 TIA %: 12 vs 24 CAD %: 81 vs 84 CHF %: 27 vs 40 Valvular heart disease %: 81 vs 48^*^ HTN %: 92 vs 92 DM %: 27 vs 28 | Mortality: 2/26 vs 3/25 RR (95% CI): 0.64 (0.12 to 3.52) Stroke: 1/26 vs 3/25 RR (95% CI): 0.32 (0.03 to 2.88) | Total serious AEs: 4 (15.4%) of 26 vs 5 (20.0%) of 25 Major GI bleeding: 1/26 vs 2/25 Re-op for bleeding: 2/26 vs 1/25 | NR

* “Baseline characteristics were well-balanced between the groups, with the exception that there was more valvular disease (P = .01) and a trend toward more valve surgery (P = .06) in the occlusion arm”31

In one trial of 43 patients undergoing open mitral valve surgery randomized to either LAA exclusion or control,29 no postoperative death or stroke occurred in either group. The composite outcome of death, stroke or transient ischemic attack (TIA), and myocardial infarction (MI) in the postoperative period was also not significantly different (9.1% vs 4.5%, P = 1.00).

The LAAOS trial randomized 77 patients at risk for stroke undergoing elective coronary artery bypass grafting (CABG) without concomitant valve surgery to either LAA exclusion or control.30 Two patients in the LAA exclusion group had perioperative stroke or TIA (2.6% vs 0%, P-value not reported). After being followed for an average of 13 +/- 7 months, no additional patients had stroke.

The LAAOS II trial randomized 51 patients with AF and increased stroke risk undergoing cardiac surgery using cardiopulmonary bypass to LAA exclusion or no occlusion with oral anticoagulation.31 At one year of follow-up there was no significant difference in the primary composite efficacy outcome of rate of death, MI, stroke, non-CNS embolism, and major bleeding (RR 0.7, 95% CI 0.2 to 2.7).

The 3 randomized controlled trials were found to have a low risk of bias. However, all were small pilot studies conducted to assess the safety and feasibility of larger trials and therefore were not powered and did not have adequate follow-up to detect clinically significant outcomes.

The 2 observational studies used propensity score matching to create comparator groups. One study reviewed 119 pairs of patients who underwent surgical ablation of AF over a mean follow-up of 3.1 +/- 2.8 years and found no significant differences in stroke-free survival (P = .88) and freedom from AF while off antiarrhythmic drugs (P = .46) between the 2 groups.32

The other study reviewed 631 pairs of patients who had undergone a variety of cardiac surgical procedures and found that while the rate of postoperative atrial fibrillation was higher in the LAA exclusion group (23% vs 18%, P = .037), fewer of these patients had stroke through postoperative day 30 (0.0% vs 6.1%, P = .003).33 However, there were more strokes in the LAA ligation group among patients without postoperative atrial fibrillation, so the overall rate of cerebrovascular accident (CVA) was not significantly different between the 2 groups (P = .44). All patients in this study underwent surgery by the same cardiothoracic surgeon, whose practices changed over the course of 10 years from performing no LAA exclusion to routine LAA exclusion during cardiac surgery. Other concurrent changes over time, such as changes in anticoagulation strategy in patients developing AF, may confound the findings of this study.

### KQ2 What are the harms associated with LAA exclusion?

The same 3 randomized controlled trials and 2 observational studies evaluated the harms of surgical LAA exclusion (Tables 5 and 6).

Table 6 Characteristics and findings of cohort studies of cardiac surgery with vs without concomitant LAA occlusion or removal

Study, Setting, Surgery performed | Technique; length of follow-up | Sample size and patient characteristics, T vs C | KQ1. Health outcome effects, T vs C | KQ2. Harms associated with LAA exclusion, T vs C | KQ4. Rates of procedural success, T vs C
Kanderian, 2008^34^ U.S.A. Valve surgery: 62% CABG + valve surgery: 31% Maze surgery: 39% | Excision (via scissors or an amputating stapling device) vs Exclusion (via suture or stapler exclusion with the LAA remaining attached). Mean time to TEE was 8.1 +/- 12 months | N: 52 excision vs 73 suture exclusion vs 12 stapler exclusion: Age: 64 vs 67 vs37 Male %: 67 vs 48 vs 75 AF %: 54 vs 30 vs 8 HTN %: 58 vs 70 vs 50 Stroke %: 17 vs 14 vs 8 CHF %: 54 vs 73 vs 25 DM %: NR Warfarin use %: 69 vs 51 vs 33 Valve surgery %: 62 vs 59 vs 75 CABG + Valve surgery %: 20 vs 41 vs 25 Maze surgery %: 67 vs 22 vs 25 | Stroke/TIA: 18 (13.1%) of 137: 6 with LAA excision 11 with suture exclusion, and 1 with stapler exclusion, (P = NS). Stroke/TIA among patients with successful vs unsuccessful LAA closure: 6 (11%) vs 12 (15%) (P = .61) | --- | Excision: 38/52 (73%), P > .001 Suture exclusion: 17/73 (23%), P > .001 Stapler exclusion: 0/12, P = .002 Total: 55/137 (40%)
Kim, 2013^33^ U.S.A. CABG %: 82.1 Valve surgery: 8.8% Combined CABG + valve surgery % = 8.6 | LAA techniques varied over time: ligation; excision and oversewn; stapled. Retrospective chart review spanning 10 years. | N: 631 vs 631 CHADS2 score: 2.25 vs 2.29 Age: 66.2 vs 65.7 After propensity score matching: Male %: 68 vs 68 Hx stroke: 5 vs 5 CHF %: 81 vs 81 HTN %: 75 vs 75 DM %: 34 vs 34 PSM model included CA BG procedure, valve replacement, gender, age risk, Hx CHF, Hx HTN, Hx DM, and Hx CVA. | After propensity score matching: Postop AF %: 22.9 vs 18.2 (P = .037) Postop CVA %: 1.0 vs 1.4 (P = .44) Postop AF with CVA %: 0 vs 1.1 (P = .003) Among subjects with postop AF, N=145 vs 115: Postop CVA %: 0 vs 6% (P = .037) | --- | ---
Lee, 2014^32^ Korea Mitral valve surgery with cryoMaze procedure | Resection. Mean follow-up: 62.6 +/- 44.0 months. TEE at 1,3,6, and 12 months; ECG at 1,3,6,12,24, and 36 months. | N: 119 vs 119 After propensity matching: Age: 53.4 vs 54.1 Male %: 37.8 vs 41.2 HTN %: 18.5 vs 19.3 CHF %: 55.5 vs 53.8 DM %: 7.6 vs 7.6 Hx stroke: 5.0 vs 5.9 Hx cardiac surgery: 6.7 vs 4.2 | Within 6 months: Mortality: 0/119 vs 1/119 Stroke: 1/119 vs 1/119 After 6 months: Mortality: 6/119 (5.0%) vs 10/119 (8.4%), RR (95% CI) 0.60 (0.22 to 1.60) Stroke/TIA 1/119 (0.8%) vs 2/119 (1.7%), RR (95% CI) 0.50 (0.05 to 5.44) AF: 11/119 vs 9/119 | Total serious AEs: 35 (29.4%) of 119 vs 29 (24.4%) of 119 Reoperation due to bleeding: 13/119 vs 6/119 Requirement for dialysis: 9/119 vs 10/119 Permanent pacemaker insertion 4/119 vs 2/119 Mediastinitis: 0/119 vs 1/119 Wound revision: 1/119 vs 2/119 Pericardial effusion 8/119 vs 6/119 | ---
Muhammad, 2014^35^ Saudi Arabia Anterior thoracotomy versus video-assisted thoracoscopy (VATS) | Anterior thoracotomy (open) vs VATS 2 years, by phone every 6 months | N: 29 (open) vs 29 (VATS) Age: 62 Male %: 60.3 HTN %: NR CHF %: NR DM %: NR | --- | Total serious AEs: 2 (6.9%) of 29 vs 0 (0.0%) of 29 | Open thoracotomy vs VATS: Operative time (min): 77.3 vs 121.3 (P < .001) Wound infection: 2/29 vs 0/29 Hospital stay, days: 11.3 vs 9.1 Duration of chest tube, days: 4.3 vs 3.7

One RCT found a trend towards longer median mechanical ventilation time in the LAA exclusion group (11.5 h vs 8 h, P = .078).29 There was no significant difference in the composite of 10 major complications (death, cerebrovascular events, MI, respiratory failure, intra-aortic balloon pump, renal dysfunction, permanent pacemaker, septicemia, mediastinitis, and reoperation for bleeding) between the exclusion and control groups (32% vs 38%, P = .75).

The LAAOS trial found more intraoperative tears involving the left atrial appendage or the left atrium in the LAA exclusion group than the control group (15% vs 4%, P-value not reported).30 However, performance of LAA occlusion did not significantly prolong cardiopulmonary bypass time (P = .63) and did not increase perioperative bleeding (P = .53), the occurrence of postoperative AF (P = .56), or diuretic use (P = .87).

The LAAOS II trial found no significant difference between the LAA exclusion and control groups for rates major bleeding (RR 0.4, 95% CI 0.0 to 4.6) or reoperation for bleeding (RR 1.9, 95% CI 0.2 to 19.9) and neither of the 2 reoperations in the LAA occlusion group was deemed secondary to bleeding at the LAA occlusion site.31 No significant difference was found for the total bypass time or cross-clamp time between the 2 groups.

Only one observational study reported harms associated with LAA exclusion and found no significant difference in early operative complications including reoperation due to bleeding (10.9% vs 5.0%, P = .17), requirement for dialysis (7.6% vs 8.4%, P > 0.99), permanent pacemaker insertion (3.4% vs 1.7%, P = .63), mediastinitis (0% vs 0.8%, P > 0.99), wound revision (0.8% vs 1.7%, P > 0.99) or pericardial effusion (6.7% vs 5.0%, P = .77).32

### KQ3 How do the benefits and harms of LAA exclusion vary in different subgroups?

We identified no trials evaluating subgroup differences in the benefits and harms of surgical LAA exclusion.

### KQ4 What are the comparative effects of different techniques on health outcomes and rates of procedural success?

Two observational studies reported the comparative effects of different surgical techniques for LAA exclusion.

One study evaluated success of surgical LAA closure as determined by postoperative TEE after a mean time of 8.1 +/- 12 months.34 Of 137 patients who underwent surgical excision, only 40% of all closures were successful. Successful LAA exclusion was found to be more common with excision (73%, P < .001) than suture exclusion (23%, P > .001) or stapler exclusion (0%, P = .002).

Another study compared anterior thoracotomy to video-assisted thoracoscopy (VATS) for LAA exclusion in 58 patients with chronic nonrheumatic AF. While there was no significant difference between the groups for hospital stay (11.3 vs 9.1 days, P = .61) or duration of chest tube (4.3 vs 3.7 days, P = .11), there was a significant increase in operative time (77.3 vs 121.3 min, P > .001) in the VATS group.35