# REFERENCES

1 January CT, Wann LS, Alpert JS, et al. 2014 AHA/ACC/HRS guideline for the management of patients with atrial fibrillation: executive summary: a report of the American College of Cardiology/American Heart Association Task Force on practice guidelines and the Heart Rhythm Society. Circulation. Dec. 2. 2014;130(23):2071-2104. [pmid: 24682348].
2 Arboix A, Alio J. Cardioembolic Stroke: Clinical Features, Specific Cardiac Disorders and Prognosis. Curr Cardiol Rev. Aug. 2010;6(3):150-161. [pmid: 21804774].
3 Blackshear JL, Odell JA. Appendage obliteration to reduce stroke in cardiac surgical patients with atrial fibrillation. Ann Thorac Surg. Feb. 1996;61(2):755-759. [pmid: 8572814].
4 Manning WJ, Silverman DI, Gordon SP, Krumholz HM, Douglas PS. Cardioversion from atrial fibrillation without prolonged anticoagulation with use of transesophageal echocardiography to exclude the presence of atrial thrombi. The New England journal of medicine. 1993;328(11):750-755. [pmid: 8437595].
5 Kansagara D, Noelck N, Papak J, et al. The effectiveness of procedures to remove or occlude the left atrial appendage. PROSPERO 2015:CRD42015016685. Available from http://www.crd.york.ac.uk/PROSPERO/display_record.asp?ID=CRD42015016685. July 28, 2015.
6 Sampson M, McGowan J, Lefebvre C, Moher D, Grimshaw J. PRESS: Peer Review of Electronic Search Strategies. Ottawa. Canadian Agency for Drugs and Technologies in Health. 2008.
7 Relevo R, Paynter R. Peer review of search strategies. Rockville (MD). Agency for Healthcare Research and Quality. (AHRQ Publication No. 12-EHC068-EF). 2012.
8 Chou R, Aronson N, Atkins D, et al. Assessing Harms When Comparing Medical Interventions. Rockville, MD. Agency for Healthcare Research and Quality (AHRQ), Methods Reference Guide for Effectiveness and Comparative Effectiveness Reviews. 2008.
9 Higgins JPT, Altman DG, editors. Chapter 8: Assessing risk of bias in included studies. Cochrane Handbook for Systematic Reviews of Interventions. 2008;Version 5.0.1. The Cochrane Collaboration. 2008. Available from www.cochrane-handbook.org. Dec 5, 2014.
10 Wells GA, Shea B, O'Connell D, et al. The Newcastle-Ottawa Scale (NOS) for assessing the quality of nonrandomized studies in meta-analyses. http://www.ohri.ca/programs/clinical_epidemiology/oxford.asp. July 30, 2015.
11 Berkman ND, Lohr KN, Ansari M, et al. Grading the Strength of a Body of Evidence When Assessing Health Care Interventions for the Effective Health Care Program of the Agency for Healthcare Research and Quality: An Update. Methods Guide for Comparative Effectiveness Reviews (Prepared by the RTI-UNC Evidence-based Practice Center under Contract No. 290-2007-10056-I). AHRQ Publication No. 13(14)-EHC130-EF. Rockville, MD. Agency for Healthcare Research and Quality. November. 2013. http://www.effectivehealthcare.ahrq.gov/ehc/products/457/1752/methods-guidance-grading-evidence-131118.pdf. July 23, 2015.
12 Alli O, Doshi S, Kar S, et al. Quality of life assessment in the randomized PROTECT AF (Percutaneous Closure of the Left Atrial Appendage Versus Warfarin Therapy for Prevention of Stroke in Patients With Atrial Fibrillation) trial of patients at risk for stroke with nonvalvular atrial fibrillation. J Am Coll Cardiol. Apr. 30. 2013;61(17):1790-1798. [pmid: 23500276].
13 Holmes DR, Reddy VY, Turi ZG, et al. Percutaneous closure of the left atrial appendage versus warfarin therapy for prevention of stroke in patients with atrial fibrillation: a randomised non-inferiority trial. [Erratum appears in Lancet. 2009 Nov 7;374(9701):1596]. Lancet. Aug. 15. 2009;374(9689):534-542. [pmid: 19683639].
14 Reddy VY, Doshi SK, Sievert H, et al. Percutaneous left atrial appendage closure for stroke prophylaxis in patients with atrial fibrillation: 2.3-Year Follow-up of the PROTECT AF (Watchman Left Atrial Appendage System for Embolic Protection in Patients with Atrial Fibrillation) Trial. Circulation. Feb. 12. 2013;127(6):720-729. [pmid: 23325525].
15 Gage BF, Waterman AD, Shannon W, Boechler M, Rich MW, Radford MJ. Validation of clinical classification schemes for predicting stroke: results from the National Registry of Atrial Fibrillation. Jama. 2001;285(22):2864-2870. [pmid: 11401607].
16 Holmes DR Jr., Kar S, Price MJ, et al. Prospective randomized evaluation of the Watchman Left Atrial Appendage Closure device in patients with atrial fibrillation versus long-term warfarin therapy: the PREVAIL trial. J Am Coll Cardiol. Jul. 8. 2014;64(1):1-12. [pmid: 24998121].
17 Bartus K, Han FT, Bednarek J, et al. Percutaneous left atrial appendage suture ligation using the LARIAT device in patients with atrial fibrillation: initial clinical experience. J Am Coll Cardiol. Jul. 9. 2013;62(2):108-118. [pmid: 23062528].
18 Nietlispach F, Gloekler S, Krause R, et al. Amplatzer left atrial appendage occlusion: single center 10-year experience. Catheter Cardiovasc Interv. Aug. 1. 2013;82(2):283-289. [pmid: 23412815].
19 Park J-W, Leithauser B, Gerk U, Vrsansky M, Jung F. Percutaneous left atrial appendage transcatheter occlusion (PLAATO) for stroke prevention in atrial fibrillation: 2-year outcomes. J Invasive Cardiol. Sep. 2009;21(9):446-450. [pmid: 19726815].
20 Block PC, Burstein S, Casale PN, et al. Percutaneous left atrial appendage occlusion for patients in atrial fibrillation suboptimal for warfarin therapy: 5-year results of the PLAATO (Percutaneous Left Atrial Appendage Transcatheter Occlusion) Study. JACC Cardiovasc Interv. Jul. 2009;2(7):594-600. [pmid: 19628179].
21 Gafoor S, Franke J, Bertog S, et al. Left atrial appendage occlusion in octogenarians: short-term and 1-year follow-up. Catheter Cardiovasc Interv. Apr. 1. 2014;83(5):805-810. [pmid: 24259397].
22 Matsuo Y, Sandri M, Mangner N, et al. Interventional closure of the left atrial appendage for stroke prevention. Circ J. 2014;78(3):619-624. [pmid: 24419803].
23 Price MJ, Gibson DN, Yakubov SJ, et al. Early safety and efficacy of percutaneous left atrial appendage suture ligation: results from the U.S. transcatheter LAA ligation consortium. J Am Coll Cardiol. Aug. 12. 2014;64(6):565-572. [pmid: 25104525].
24 Ostermayer SH, Reisman M, Kramer PH, et al. Percutaneous left atrial appendage transcatheter occlusion (PLAATO system) to prevent stroke in high-risk patients with non-rheumatic atrial fibrillation: results from the international multi-center feasibility trials. J Am Coll Cardiol. Jul. 5. 2005;46(1):9-14. [pmid: 15992628].
25 Reddy VY, Mobius-Winkler S, Miller MA, et al. Left atrial appendage closure with the Watchman device in patients with a contraindication for oral anticoagulation: the ASAP study (ASA Plavix Feasibility Study With Watchman Left Atrial Appendage Closure Technology). J Am Coll Cardiol. Jun. 25. 2013;61(25):2551-2556. [pmid: 23583249].
26 Reddy VY, Holmes D, Doshi SK, Neuzil P, Kar S. Safety of percutaneous left atrial appendage closure: results from the Watchman Left Atrial Appendage System for Embolic Protection in Patients with AF (PROTECT AF) clinical trial and the Continued Access Registry. Circulation. Feb. 1. 2011;123(4):417-424. [pmid: 21242484].
27 Gangireddy SR, Halperin JL, Fuster V, Reddy VY. Percutaneous left atrial appendage closure for stroke prevention in patients with atrial fibrillation: an assessment of net clinical benefit. Eur Heart J. Nov. 2012;33(21):2700-2708. [pmid: 23008509].
28 Bayard Y-L, Omran H, Neuzil P, et al. PLAATO (Percutaneous Left Atrial Appendage Transcatheter Occlusion) for prevention of cardioembolic stroke in non-anticoagulation eligible atrial fibrillation patients: results from the European PLAATO study. EuroIntervention. Jun. 2010;6(2):220-226. [pmid: 20562072].
29 Nagpal AD, Torracca L, Fumero A, Denti P, Cioni M, Alfieri O. Concurrent prophylactic left atrial appendage exclusion: results from a randomized controlled trial pilot study. Eur J Cardiothorac Surg. Sep. 2009;36(3):553-557. [pmid: 19473853].
30 Healey JS, Crystal E, Lamy A, et al. Left Atrial Appendage Occlusion Study (LAAOS): results of a randomized controlled pilot study of left atrial appendage occlusion during coronary bypass surgery in patients at risk for stroke. Am Heart J. Aug. 2005;150(2):288-293. [pmid: 16086933].
31 Whitlock RP, Vincent J, Blackall MH, et al. Left Atrial Appendage Occlusion Study II (LAAOS II). Can J Cardiol. Nov. 2013;29(11):1443-1447. [pmid: 24054920].
32 Lee C-H, Kim JB, Jung S-H, Choo SJ, Chung CH, Lee JW. Left atrial appendage resection versus preservation during the surgical ablation of atrial fibrillation. Ann Thorac Surg. Jan. 2014;97(1):124-132. [pmid: 24075500].
33 Kim R, Baumgartner N, Clements J. Routine left atrial appendage ligation during cardiac surgery may prevent postoperative atrial fibrillation-related cerebrovascular accident. J Thorac Cardiovasc Surg. Feb. 2013;145(2):582-589. discussion 589. [pmid: 23137520].
34 Kanderian AS, Gillinov AM, Pettersson GB, Blackstone E, Klein AL. Success of surgical left atrial appendage closure: assessment by transesophageal echocardiography. J Am Coll Cardiol. Sep. 9. 2008;52(11):924-929. [pmid: 18772063].
35 Muhammad MIA. Role of video-assisted thoracoscopy in the management of stroke. Asian Cardiovasc Thorac Ann. Feb. 2014;22(2):155-159. [pmid: 24585785].
36 Chatterjee S, Herrmann HC, Wilensky RL, et al. Safety and Procedural Success of Left Atrial Appendage Exclusion With the Lariat Device: A Systematic Review of Published Reports and Analytic Review of the FDA MAUDE Database. JAMA internal medicine. Jul. 1. 2015;175(7):1104-1109. [pmid: 25938303].
37 Bajaj NS, Parashar A, Agarwal S, et al. Percutaneous left atrial appendage occlusion for stroke prophylaxis in nonvalvular atrial fibrillation: a systematic review and analysis of observational studies. JACC Cardiovasc Interv. Mar. 2014;7(3):296-304. [pmid: 24650403].
38 Munkholm-Larsen S, Cao C, Yan TD, Pehrson S, Dixen U. Percutaneous atrial appendage occlusion for stroke prevention in patients with atrial fibrillation: a systematic review. Heart. Jun. 2012;98(12):900-907. [pmid: 22511532].
39 Bode WD, Patel N, Gehi AK. Left atrial appendage occlusion for prevention of stroke in non-valvular atrial fibrillation: A meta-analysis. Circulation. 2014;130. ((Bode W.D.; Gehi A.K.) Dept of Medicine, Div of Cardiology, Univ of North Carolina at Chapel Hill, Chapel Hill, United States).
40 Holmes DR Jr., Doshi SK, Kar S, et al. Left Atrial Appendage Closure as an Alternative to Warfarin for Stroke Prevention in Atrial Fibrillation: A Patient-Level Meta-Analysis. J Am Coll Cardiol. Jun. 23. 2015;65(24):2614-2623. [pmid: 26088300].
41 Connolly SJ, Pogue J, Hart RG, et al. Effect of clopidogrel added to aspirin in patients with atrial fibrillation. N Engl J Med. May. 14. 2009;360(20):2066-2078. [pmid: 19336502].
42 Active Writing Group of the ACTIVE Investigators, Connolly S, Pogue J, et al. Clopidogrel plus aspirin versus oral anticoagulation for atrial fibrillation in the Atrial fibrillation Clopidogrel Trial with Irbesartan for prevention of Vascular Events (ACTIVE W): a randomised controlled trial. Lancet. 2006;367(9526):1903-1912. [pmid: 16765759].
43 Pisters R, Lane DA, Nieuwlaat R, de Vos CB, Crijns HJ, Lip GY. A novel user-friendly score (HAS-BLED) to assess 1-year risk of major bleeding in patients with atrial fibrillation: the Euro Heart Survey. Chest. Nov. 2010;138(5):1093-1100. [pmid: 20299623].
44 Moher D, Pham B, Lawson ML, Klassen TP. The inclusion of reports of randomised trials published in languages other than English in systematic reviews. Health technology assessment (Winchester, England). 2003;7(41):1-90.
45 Viles-Gonzalez JF, Kar S, Douglas P, et al. The clinical impact of incomplete left atrial appendage closure with the Watchman Device in patients with atrial fibrillation: a PROTECT AF (Percutaneous Closure of the Left Atrial Appendage Versus Warfarin Therapy for Prevention of Stroke in Patients With Atrial Fibrillation) substudy. J Am Coll Cardiol. Mar. 6. 2012;59(10):923-929. [pmid: 22381428].