# METHODS

## TOPIC DEVELOPMENT

The topic of this review was nominated by Dr. Alaa Shalaby, a member of the VHA Cardiology Field Advisory Committee and Director of Cardiac Electrophysiology at the VA Pittsburgh Healthcare System. Dr. William Gunnar, National Director of Surgery for the Veterans Health Administration, also served as an operational partner.

The research questions for this systematic review were developed after a topic refinement process that included a preliminary review of published peer-reviewed literature, consultation with internal partners and investigators, and consultation with content experts and key stakeholders. The key questions (KQs) that this review sought to address are as follows:

KQ1. What is the effectiveness of surgical or percutaneous LAA exclusion compared with usual care?

KQ2. What are the harms associated with surgical or percutaneous LAA exclusion?

KQ3. How do the benefits and harms of LAA exclusion vary in different subgroups?

KQ4. What are the comparative effects of different techniques (surgical and percutaneous) of LAA exclusion on rates of procedural success?

A protocol describing the review plan was posted to a publicly accessible website before the study was initiated.5

## SEARCH STRATEGY

Search strategy was developed in consultation with a research librarian, and was peer reviewed by a second research librarian using the instrument for Peer Review of Search Strategies (PRESS).6,7 To identify relevant articles, we searched Ovid MEDLINE^®^, Embase^®^, the Cochrane databases, and the FDA Devices database from database inception through January 7, 2015. We further reviewed the bibliographies of systematic reviews and other relevant articles for additional studies. To identify in-progress or unpublished studies, we searched ClinicalTrials.gov, the Conference Abstracts database, the World Health Organization International Clinical Trials Registry Platform (WHO ICTRP), and contacted device manufacturers to inquire for unpublished trial data.

Using pre-specified inclusion/exclusion criteria, we reviewed titles and abstracts for relevance to the key questions. At the full-text screening stage, 2 independent reviewers concurred on final inclusion/exclusion decisions, with input from a third investigator when needed to resolve questions and reach consensus. Articles meeting eligibility criteria were included for data abstraction.

## STUDY SELECTION

The criteria for patient population, intervention, comparator, outcome, timing parameters, and study designs (PICOTS) that apply to each key question are specified in Table 1 (percutaneous procedures) and Table 2 (surgical procedures). Given the availability of larger-scale trials of percutaneous procedures, along with recent systematic reviews of percutaneous approaches to LAA exclusion, we only included controlled clinical trials to assess the effectiveness of percutaneous LAA exclusion procedures. On the other hand, we included cohort studies with or without a control population to examine harms of percutaneous interventions.8 After an initial survey of the literature, we found there were a number of larger cohort studies providing harms data and therefore set a sample size cut-off of 50 or more patients for inclusion.

Table 1 PICOTS and Key Questions for Percutaneous LAA Interventions

Key Question | KQ1. What is the effectiveness of LAA exclusion interventions compared with usual care? | KQ2. What are the harms associated with LAA exclusion? | KQ3a. How do the benefits LAA exclusion vary in different subgroups? KQ3b. How do the harms of LAA exclusion vary in different subgroups? | KQ4. What are the comparative effects of different techniques on rates of procedural success?
Population | Patients with atrial fibrillation who are eligible for percutaneous LAA exclusion
Intervention | - AMPLATZER™ Cardiac Plug (company: AGA Medical, Corp., North Plymouth, MN, USA); - WATCHMAN® Left Atrial Appendage Closure Technology/Device/System (company: Atritech, Inc., North Plymouth, MN, USA); - PLAATO™ Percutaneous Left Atrial Appendage Transcatheter Occlusion (company: Appriva Medical, Inc., Sunnyvale, CA); - Coherex WaveCrest™ LAA Occluder System (company: Coherex Medical, Inc., Salt Lake City, Utah, USA); - LARIAT suture delivery device (SentreHeart, Redwood City, California); - Lifetech LAmbre™ Left Atrial Appendage Occluder Device (Lifetech Scientific Co., Ltd) Nanshan District, Shenzhen, PEOPLE'S REPUBLIC OF CHINA
Comparator | Usual care without LAA exclusion | | | Compares percutaneous intervention to another LAA closure technique (surgical, thoracoscopic, or percutaneous)
Outcomes | Primary outcomes:; ▪ Stroke; ▪ Mortality; ▪ Cardiovascular morbidity; ▪ Other reported health outcomes | ▪ Harms other than primary outcomes for KQ1; ▪ length of stay (hospital and ICU); ▪ bleeding; ▪ infection; ▪ need for surgical intervention | ▪ Primary outcomes listed in KQ1; ▪ Other reported benefits and harms; ▪ Rates of bleeding. | [underlined: Procedural outcome:] Successful closure/LAA removal, assessed by methods such as transesophageal echocardiogram; CT; MRI. [underlined: Health outcomes:] Same as those listed for KQ1.
Timing | Short- and long-term outcomes
Study design | [underlined: Include:] Systematic reviews, meta-analyses, or randomized controlled trials. For KQ2 and KQ3b, we will additionally include cohort and trial extension studies that report data on adverse events. [underlined: Exclude:] Non-systematic or narrative reviews, non-randomized trials, opinions, case studies, case series, and quasi-experimental studies.

Table 2 PICOTS and Key Questions for Surgical LAA Interventions

Key Question | KQ1. What is the effectiveness of LAA exclusion interventions compared with usual care? | KQ2. What are the harms associated with LAA exclusion? | KQ3. How do the benefits and harms of LAA exclusion vary in different subgroups? | KQ4. What are the comparative effects of different techniques on health outcomes and rates of procedural success?
Population | Patients undergoing cardiac surgery: coronary bypass surgery; valvular surgery; or both bypass and valve surgery. | Patients undergoing surgical LAA occlusion/removal in combination with surgery for atrial fibrillation (ie, MAZE). | Patients undergoing surgical LAA exclusion. | Non-selected population of patients with atrial fibrillation
Intervention | - LAA occlusion/removal techniques that involve major surgery (sternotomy or thoracotomy), eg:; ▪ specific devices such as AtriClip, or; ▪ techniques such as stapling or suturing; - LAA occlusion/removal via thoracoscopic surgery; - Minimally invasive Maze procedures if there are data about the incremental effects of concomitant LAA exclusion.
Comparator | Cardiac surgery without LAA removal or occlusion. | Surgery for atrial fibrillation without LAA removal. | Non-surgical/usual care for thromboembolic stroke prevention, such as aspirin for patients with CHADS2 of 0 or 1, and antithrombotic therapy with warfarin or a NOAC (apixiban, dabigatran, rivaroxaban) for CHADS2 of >=1. | Compares surgical intervention to another LAA closure technique (surgical, thoracoscopic, or percutaneous)
Outcomes | Primary outcomes:; ▪ Stroke; ▪ Mortality; ▪ Cardiovascular morbidity; ▪ Other reported health outcomes | ▪ Harms other than primary outcomes for KQ1; ▪ length of stay (hospital and ICU); ▪ time on bypass; ▪ bleeding; ▪ ventilator days; ▪ infection | ▪ Primary outcomes listed in KQ1; ▪ Other reported benefits and harms; ▪ Rates of bleeding. | [underlined: Procedural outcome:] Successful closure/LAA removal, assessed by methods such as transesophageal echocardiogram; CT; MRI. [underlined: Health outcomes:] Same as those listed for KQ1.
Timing | Short- and long-term outcomes
Study design | [underlined: Include:] Systematic reviews, meta-analyses, controlled clinical trials (randomized or non-randomized), and methodologically rigorous observational studies (case control/cohort studies) that adjust for important confounders, eg, propensity score matching [underlined: Exclude:] Non-systematic or narrative reviews, opinions, case studies, case series, and quasi-experimental studies.

We included cohort studies in addition to controlled clinical trials for all key questions examining benefits and harms of surgical procedures.8 However, given that the LAA exclusion procedures were usually done in the context of heart surgery and that the harms related to LAA exclusion would be difficult to distinguish from those of the heart surgery itself, we only included cohort studies with a control population of patients who received heart surgery but no LAA exclusion.

## DATA ABSTRACTION

One investigator (among NN, JP, and MF) abstracted data from published reports into a customized database, and entries were confirmed by a second reviewer. From each study, we abstracted study design, objectives, setting, population characteristics (including sex, age, race/ethnicity), subject eligibility and exclusion criteria, number of subjects, years of enrollment, duration of follow-up, the study and comparator interventions, important co-interventions, health outcomes, and adverse events. A second author reviewed the entries for accuracy.

## QUALITY ASSESSMENT

Two reviewers (among NN, DK, JP, and MF) independently assessed the quality of each trial using a tool developed by the Cochrane Collaboration (Appendix C).9 We assigned each trial an overall summary assessment of low, high, or unclear risk of bias.

For evaluating cohort studies of surgical LAA interventions, we used the Newcastle-Ottawa criteria to assess methodological rigor and consider potential sources of bias.10 We did not assign overall quality ratings, however, as validated criteria for ranking observational studies are not currently available.

## DATA SYNTHESIS

We qualitatively synthesized the evidence on the benefits and harms of LAA exclusion. Clinical heterogeneity and the small number of trials precluded the possibility of combining the findings in meta-analysis.

## RATING THE BODY OF EVIDENCE

We assessed the overall quality of evidence for each outcome using a method developed by the Agency for Healthcare Research and Quality (AHRQ).11 We considered the consistency, coherence, and applicability of the body of evidence, as well as the internal validity of individual studies, to classify the strength of evidence for each outcome as follows:

- High = Further research is very unlikely to change our confidence on the estimate of effect.
- Moderate = Further research is likely to have an important impact on our confidence in the estimate of effect and may change the estimate.
- Low = Further research is very likely to have an important impact on our confidence in the estimate of effect and is likely to change the estimate.
- Insufficient = Any estimate of effect is very uncertain.

## PEER REVIEW

A draft version of this report was reviewed by 5 individuals with technical expertise and clinical leadership. Their comments and our responses are presented in Appendix E.