# INTRODUCTION

Atrial fibrillation (AF) is the most common cardiac arrhythmia, affecting between 2.7 and 6.1 million people in the United States.1 The prevalence of AF increases with age and is often associated with structural heart disease and co-morbidities that are common in the Veteran population. Complications related to AF can be classified as hemodynamic or thromboembolic.

Cardioembolic strokes account for 14-36% of all ischemic strokes, and AF is the most important cause of cardioembolic stroke. In general, the risk of stroke in patients with non-valvular AF is 2 to 7 times higher than patients without AF.2 Antithrombotic therapy with aspirin, warfarin, or one of several newer oral anticoagulants have been the mainstay of stroke prevention in atrial fibrillation, but may be cumbersome and are associated with an increased risk of bleeding.

The mechanism of thrombosis formation is stasis of blood in the left atrium and it is currently believed that a high percentage of thromboemboli develop in the left atrial appendage (LAA).3,4 Thus, various procedures have been developed that attempt to isolate the LAA from circulating blood flow in an effort to reduce the risk of thromboembolic stroke. These methods include surgical occlusion or removal of the LAA, and percutaneous, catheter-based approaches to occlude the LAA. The LAA is, however, only one potential source of strokes and patients at the highest risk of stroke related to AF frequently have associated risk factors for stroke that are independent of AF. These risk factors – including hypertension, diabetes, and advanced age – increase a patient's likelihood of an ischemic stroke secondary to atherosclerotic aortic or carotid disease which would not be addressed by exclusion or removal of the LAA.

Prior to 2002, surgery was the only option for exclusion of the LAA. This could be done in conjunction with surgery being performed for other reasons, such as coronary artery bypass grafting (CABG) or valve replacement in patients who also have or are at risk for AF, or as part of a mini-thoracotomy typically in association with a maze procedure. Surgical approaches to LAA exclusion include simple suture ligation, oversewing the base without excision, excising the appendage and oversewing the base, or surgical stapling and excision.1

More recently, a number of devices designed to occlude the LAA percutaneously have been developed. The devices currently in use include the Percutaneous Left Atrial Appendage Transcatheter Occlusion (PLAATO) device (Appriva Medical, Plymouth, Minnesota), the Amplatzer device (AGA Medical Corporation/St. Jude Medical, Golden Valley, Minnesota), the Watchman device (Boston Scientific, Natick, Massachusetts), and the LARIAT suture delivery device (SentreHeart, Redwood City, California). Given the high prevalence of atrial fibrillation in the general and Veteran population, along with the potential risks and inconvenience of long-term oral anticoagulant therapy, there is a growing interest in LAA occlusion or removal as an alternative stroke risk reduction strategy. The purpose of this report is to systematically review the literature to better understand the balance of benefits and harms of surgical or percutaneous LAA occlusion or removal. We use the general term LAA exclusion throughout the report to refer to either removal or isolation of the LAA, except where otherwise specified.