# EXECUTIVE SUMMARY

## INTRODUCTION

Atrial fibrillation (AF) is the most common cardiac arrhythmia, affecting between 2.7 and 6.1 million people in the United States. The prevalence of AF increases with age and is often associated with structural heart disease and co-morbidities that are common in the Veteran population. AF is the most important cause of cardioembolic stroke, which accounts for 14-36% of all ischemic strokes. While patients at highest risk for AF-related stroke also often have other independent risk factors for stroke secondary to atherosclerotic aortic or carotid disease, most cardiac sources of embolism are thought to be due to thrombus formation from blood stasis in the left atrium. Among patients with non-valvular AF more than 90% of thrombi develop in the left atrial appendage (LAA). Antithrombotic therapy with aspirin, warfarin, or one of several newer oral anticoagulants reduces the risk of stroke due to both atrial fibrillation and atherosclerotic disease but is associated with a risk of serious bleeding. As a potential alternative to long-term anticoagulant therapy, various LAA exclusion procedures have been developed in an attempt to isolate the LAA from circulating blood flow. These procedures, including both surgical occlusion and removal of the LAA and percutaneous catheter-based interventions to occlude the LAA, may be beneficial in reducing risk of cardioembolic stroke originating from the LAA.

The purpose of this report is to systematically review the literature to better understand the balance of benefits and harms of surgical or percutaneous LAA exclusion procedures.

## METHODS

The research questions for this systematic review were developed in consultation with key stakeholders and content experts. The key questions (KQs) that this review sought to address were:

KQ1. What is the effectiveness of surgical or percutaneous LAA exclusion compared with usual care?

KQ2. What are the harms associated with surgical or percutaneous LAA exclusion?

KQ3. How do the benefits and harms of LAA exclusion vary in different subgroups?

KQ4. What are the comparative effects of different techniques (surgical and percutaneous) of LAA exclusion on rates of procedural success?

### Data Sources and Searches

We developed search strategies in consultation with a research librarian, who conducted database searches in Ovid MEDLINE^®^, Embase^®^, the Cochrane databases, the FDA Devices database, ClinicalTrials.gov, the Conference Abstracts database, and the World Health Organization International Clinical Trials Registry Platform (WHO ICTRP) from database inception through January 7, 2015. We reviewed the bibliographies of systematic reviews and other relevant articles for additional studies, and contacted device manufacturers to inquire for unpublished trial data.

### Study Selection

We reviewed titles and abstracts using pre-specified inclusion/exclusion criteria. Potentially relevant full-text articles underwent independent review by at least 2 investigators for final decisions on inclusion/exclusion.

We included controlled clinical trials to assess the effectiveness of percutaneous LAA exclusion procedures. To assess the harms of percutaneous LAA procedures we also included cohort and registry studies with 50 or more patients.

We included cohort studies and controlled clinical trials to review both benefits and harms of surgical LAA procedures. Because LAA exclusion procedures were usually done in the context of heart surgery, and harms related to LAA exclusion are difficult to distinguish from those of the heart surgery itself, we only included cohort studies with a control group of patients who received heart surgery without LAA exclusion.

### Data Abstraction and Quality Assessment

One author abstracted data from each study and a second author reviewed the entries for accuracy.

Two reviewers (among NN, DK, JP, and MF) independently assessed the quality of each study using published criteria. We graded the strength of evidence for each outcome using published criteria which consider the consistency, coherence, directness, and applicability of a body of evidence, as well as the internal validity of individual studies. We resolved disagreements through discussion.

### Data Synthesis and Analysis

We qualitatively synthesized the evidence on the benefits and harms of LAA exclusion. Clinical heterogeneity and the small number of trials precluded the possibility of combining the findings in meta-analysis.

### Peer Review

A draft version of this report was reviewed by 5 individuals with technical expertise and clinical leadership. Their comments and our responses are presented in Appendix E.

## SUMMARY OF FINDINGS

We reviewed 2,566 titles and abstracts from the combined searches. We selected 207 articles for full-text review, of which 20 studies contained primary data relevant to the effectiveness and/or harms of LAA interventions. We contacted 7 device companies to request information about unpublished studies but received no response.

### Summary of Evidence

There is low-strength evidence that percutaneous LAA exclusion is associated with a similar risk of long-term stroke and mortality as continued oral anticoagulation therapy. This finding is based on trials of one device studied in patients without contraindications to oral anticoagulant therapy. Most patients who received the Watchman device were able to discontinue oral anticoagulant therapy after undergoing follow-up transesophageal echocardiography (TEE) showing persistent closure of the LAA at 3-6 months. However, there is moderate strength evidence that a substantial proportion of patients undergoing various percutaneous LAA exclusion procedures experienced serious periprocedural harms. For example, patients undergoing placement of a Watchman device experienced 4.1-10.5% periprocedural adverse events. There is insufficient evidence to determine whether factors such as operator experience, patient selection criteria, or choice of device can modify these risks. There is insufficient data to assess the balance of benefits and harms of percutaneous LAA exclusion procedures in patients who are ineligible for long-term oral anticoagulation therapy.

We found insufficient evidence to determine the efficacy of surgical LAA exclusion in reducing stroke. We found low-strength evidence that surgical LAA exclusion in the context of heart surgery done for another indication is unlikely to be associated with significant incremental harm. In 2 studies, successful closure of the LAA was demonstrated in follow-up in only 40-66% of patients.

Table 1 summarizes the evidence on percutaneous and surgical LAA exclusion interventions.

Table 1 Summary of evidence on the effectiveness of procedures to remove or occlude the left atrial appendage

Outcome | Device or procedure N studies (N=combined participants) | Findings | Strength of Evidence* | Comments
Percutaneous interventions
Mortality | Watchman 2 RCTs (N=1,114) | No significant difference in mortality. RR (95% CI) in 2 RCTs: 1.20 (0.31 to 4.56) 0.62 (0.34 to 1.24) | Low | Limited applicability: only one device has been studied in 2 RCTs. Patients were eligible to receive LT-OAC. Low precision (wide confidence intervals).
Stroke | Watchman 2 RCTs (N=1,114) | No significant difference in risk of stroke. RR (95% CI): in 2 RCTs: 0.71 (0.35 to 1.64) 3.28 (0.37 to 25.31) | Low | Limited applicability: only one device has been studied in 2 RCTs. Patients were eligible to receive LT-OAC. Low precision (wide confidence intervals).
Harms | ACP: 3 registries (N=147) Coherex: 1 registry (N=4) Lariat: 2 registries (N=93) PLAATO: 5 registries (n=441) Watchman: 2 RCTs + 4 registries (N=742) Device not specified: 2 registries (N=211) | Serious procedure- or device-related safety events (% of patients): 1.6 to 13.6. Overall, rate of serious adverse events within 7 days of device implantation was 6.5% (98/1506). | Moderate | A range of devices were examined among 2 trials and 11 observational studies. Strength of finding limited by wide range of event rates across studies, relatively small number of patients treated in each observational study.
Surgical interventions
Mortality | Sutures or stapler in 3 RCTs (N=171) Various excision and exclusion techniques in 4 Cohort studies (N=1695) | No significant difference in mortality, among studies in which at least one event occurred in both groups: In 1 RCT: 7.7 vs 12% (P > .05) RR (95% CI) 0.64 (0.12, 3.52) In 1 cohort: 5.0 vs 8.4% (P > .05) RR (95% CI) 0.60 (0.22 to 1.60) | Insufficient | Trials too small and event rates too low to determine effectiveness of procedure.
Stroke | 3 RCTs (N=171) 2 cohort studies (N=1500) | No significant difference in risk of stroke, among studies in which at least one event occurred in both groups: In 1 RCT: 3.8 vs 12% (P > .05); RR (95% CI) 0.32 (0.03 to 2.88) In 2 cohorts: 1.0 vs 1.4% (P = .44) 0.84 vs 1.7% (P > .05) | Insufficient | Trials too small and event rates too low to determine effectiveness of procedure.
Harms | 3 RCTs (N=171) 1 cohort study (N=238) | Serious safety events: 6.9-32.0% of patients No significant differences in most major harms between cardiac surgery groups with and without LAA exclusion | Low | Limited number of studies and limited number of patients included.

Abbreviations: ACP = Amplatzer cardiac plug; CI = confidence interval; LT-OAC = long term oral anticoagulation; RCT = randomized controlled trial; PLAATO = percutaneous left atrial appendage transcatheter occlusion; RR = relative risk

### Research Gaps/Future Research

Trials of percutaneous LAA interventions were limited to studies of the Watchman device in patients who were eligible for long-term warfarin therapy. Trials of surgical LAA interventions were few and limited by sample size. Several studies that should add substantively to this body of evidence are underway, including a large RCT of surgical interventions with an estimated sample size of 4,700 patients, studies of recently developed percutaneous devices (LAmbre and Occlutech), and a trial comparing Watchman with Apixaban in patients ineligible for warfarin therapy.

### Conclusions

Overall, there is limited evidence that percutaneous LAA exclusion using the Watchman device may be an effective alternative to long-term oral anticoagulation in selected patients who are closely followed and in whom procedural success is sustained. However, in many studies, percutaneous LAA exclusion has been associated with high rates of serious procedure-related harms. There is insufficient evidence to assess the benefits of surgical LAA exclusion. While surgical LAA exclusion does not appear to be associated with a significant increase in harms over the heart surgery during which the procedures are typically performed, rates of procedural success may be low. Overall, there is insufficient evidence to support the routine use of surgical LAA exclusion to reduce stroke risk or future need for anticoagulant therapy.