# PEER REVIEWER COMMENTS AND AUTHOR RESPONSES

Question | Reviewer | Comment | Response
Are the objectives, scope, and methods for this review clearly described? | 1 | Yes | Noted.
Are the objectives, scope, and methods for this review clearly described? | 2 | Yes | Noted.
Are the objectives, scope, and methods for this review clearly described? | 3 | Yes | Noted.
Are the objectives, scope, and methods for this review clearly described? | 4 | Yes | Noted.
Are the objectives, scope, and methods for this review clearly described? | 5 | Yes | Noted.
Is there any indication of bias in our synthesis of the evidence? | 1 | No | Noted.
Is there any indication of bias in our synthesis of the evidence? | 2 | No | Noted.
Is there any indication of bias in our synthesis of the evidence? | 3 | Yes - The method section clearly identifies the process for evidence collection and synthesis. | Noted.
Is there any indication of bias in our synthesis of the evidence? | 4 | No | Noted.
Is there any indication of bias in our synthesis of the evidence? | 5 | No | Noted.
Are there any [underlined: published] or [underlined: unpublished] studies that we may have overlooked? | 1 | Yes - Medtronic sponsored and run The Cardioblate Closure Device Study (FDA IDE G080156) “An evaluation of the Cardioblate Closure Device in Facilitating Occlusion of the Left Atrial Appendage”. Enrollment was suspended in 2009. The data was not published but is available by the FDA. | We came across this study in our search for trials in clinicaltrials.gov. We decided not to include it because the study was terminated due to a Medtronic business decision, and no study results were posted. We were unable to find the study on the FDA website.
Are there any [underlined: published] or [underlined: unpublished] studies that we may have overlooked? | 2 | No | Noted.
Are there any [underlined: published] or [underlined: unpublished] studies that we may have overlooked? | 3 | No | Noted.
Are there any [underlined: published] or [underlined: unpublished] studies that we may have overlooked? | 4 | No | Noted.
Are there any [underlined: published] or [underlined: unpublished] studies that we may have overlooked? | 5 | No | Noted.
Additional suggestions or comments can be provided below. If applicable, please indicate the page and line numbers from the draft report. | 1 | | No comment.
Additional suggestions or comments can be provided below. If applicable, please indicate the page and line numbers from the draft report. | 2 | This analysis of the safety and efficacy of procedures to occlude or remove the left atrial appendage is comprehensive, informative, and well written. The conclusions are well supported and though the paper does not provide definitive guidance on the role of LAA exclusion in reducing the risk of AF associated stroke it will be very useful for clinicians and policy makers. | Noted, thank you.
Additional suggestions or comments can be provided below. If applicable, please indicate the page and line numbers from the draft report. | 2 | I have a minor disagreement with the point in the introduction that since 90% of thrombi that develop in the atrium are in the appendage it would make sense that elimination of the appendage would reduce the risk of stroke. This point is certainly true but a more nuanced discussion of the etiology on stroke in AF would be helpful in understanding why exclusion of the appendage may not eliminate the risk of stroke in AF. It is worth mentioning that the appendage is not the only source of strokes in AF patients. The patients at highest risk AF associated stroke have risk factors for stoke that are independent of AF such as hypertension, diabetes, and advanced age. Each of these puts patients at risk for mechanisms of stroke that are not related to AF such as aortic and carotid atherosclerosis. I do not know if it is really known what percentage of strokes in patients with AF are from appendage thrombus versus other mechanisms. Thus the point is that though 90% of clots in the heart are in the appendage it is not known what percentage of AF associated strokes are due to the embolism of clots from the appendage. This is especially true as one does more extensive monitoring for occult AF in stroke patients. | Edits made to reflect our uncertainty regarding source of thrombi in the introduction of the executive summary and evidence report.
Additional suggestions or comments can be provided below. If applicable, please indicate the page and line numbers from the draft report. | 2 | Minor points: Maze is not consistently capitalized (single or all caps) in the manuscript | Corrected. We will use “all caps” MAZE.
Additional suggestions or comments can be provided below. If applicable, please indicate the page and line numbers from the draft report. | 2 | Page 10 Table 2 (and elsewhere): There is some inconsistency in whether the CHADS2 score or the CHA2DS2-VASC is used for risk stratification. If possible the CHA2DS2-VASC should be used though I understand that not all studies will report it. | We will continue to use CHADS2 and CHADS2-VASC as appropriate for individual studies, however, when making general comments/summary statements we will use low risk (CHADS2 <2 or CHADS2-Vasc <2) when patients/providers have been given the option of aspirin versus warfarin therapy.
Additional suggestions or comments can be provided below. If applicable, please indicate the page and line numbers from the draft report. | 2 | In the PREVAIL trial statistical methods it states, “Data on endpoints from PROTECT AF subjects meeting the inclusion/exclusion criteria for PREVAIL were used in a historical previous distribution, with 50% discounting to reduce the influence of the earlier data. “ To me this sounds that some patients acted as controls in both PROTECT and PRVAIL. Was this taken into account in your analysis? Should it be? | The PREVAIL study used the data from PROTECT in power calculations to determine the study size. Patients from PREVAIL were not included in the PREVAIL trial.
Additional suggestions or comments can be provided below. If applicable, please indicate the page and line numbers from the draft report. | 2 | Page 15: It does not seem to make sense to me that the composite endpoint would be 5.2% in the LAA exclusion group and 2.9% in the warfarin group but that the 18 month composite event rate ration was only 1.07. | We agree this is confusing, and have added wording to clarify the % vs rate ratio which is based on person-time of observation. It is likely because the event rates are reported for the total duration of the study (longer than 18 months) and some of the events in the device group occurred later in the study.
Additional suggestions or comments can be provided below. If applicable, please indicate the page and line numbers from the draft report. | 2 | Table 3: The PROTECT AF quality of life data is suspect in my mind in that the study was unblinded and one group had a complex procedure. Such a procedure it would seem to me could have a profound placebo effect that might influence the patient's assessment of quality of life. | We agree, and have rated the ROB for QOL outcomes as follows: High for QOL outcomes owing to lack of blinding, subjective nature of the outcome, and differential rates of follow-up for this outcome.
Additional suggestions or comments can be provided below. If applicable, please indicate the page and line numbers from the draft report. | 2 | Page 29: It might be worth mentioning that in one large study of warfarin versus aspirin and clopidogrel for AF associated stroke prevention the risk of major bleeding was similar between with warfarin compared to the combination of ASA and clopidogrel and that minor bleeding and overall bleeding were higher with ASA and clopidogrel compared to warfarin. Thus as long as the protocol for the use of the watchman device requires that drug combination for up to 6 months it will not be an attractive device for patients that are at high risk for bleeding complications and do not want to take warfarin. | We appreciate this point and have added it to our discussion.
Additional suggestions or comments can be provided below. If applicable, please indicate the page and line numbers from the draft report. | 2 | There is a very wide range of reported % rate of stroke in various studies reported in the manuscript. I believe some of this variation is due to variable follow-up time and differing risk stroke factor profiles. There probably is no easy way to correct for these factors and make the numbers comparable across studies but it would be nice if possible. Perhaps as you have done just having follow-up time and risk factors in the tables is the best you can do. | Challenging. This represents that variable populations which were enrolled and different follow-up time. We hope to provide the data in a clear format so that the differences are relatively clear.
Additional suggestions or comments can be provided below. If applicable, please indicate the page and line numbers from the draft report. | 3 | The report is overall very well-conceived and written. I am not clear why the RCTs that are listed in appendix C while satisfying most of the questions are still considered low quality evidence. I did not find enough support for that determination in the narrative as well. | Low = Low risk of bias.
Additional suggestions or comments can be provided below. If applicable, please indicate the page and line numbers from the draft report. | 4 | In the summary of evidence (page 2) please expand the statement pertaining to LAA percutaneous LAA exclusion (line 51) to include comment for all devices not just Watchman. | We agree and have made the suggested change.
Additional suggestions or comments can be provided below. If applicable, please indicate the page and line numbers from the draft report. | 4 | I am unclear as to the statements made regarding surgical ablation of the LAA during routine cardiac procedures (page 30, lines 4-27). Specifically, why could the clinician not avoid anticoagulation if the patient had a prior LAA ablation (whether open surgical or percutaneous)? Please consider clarifying that no evidence exists to evaluate whether prophylactic LAA oblation prevents or minimizes stroke risk associated with later onset AF. | We have edited this to reflect the uncertainty of the literature regarding reduction in stroke risk from surgical LAA exclusion.
Additional suggestions or comments can be provided below. If applicable, please indicate the page and line numbers from the draft report. | 5 | Noelck and colleagues from the ESP Center performed a systematic review of the effectiveness and harms of percutaneous catheter-based and surgical interventions to occlude, exclude, or remove the left atrial appendage (LAA). They were charged with addressing 4 key questions regarding effectiveness compared to usual care (ie anticoagulation or antiplatelet agents), harms, variance of effects among subgroups, and comparative effects of different techniques. They concluded that the Watchman device may be an effective alternative to long-term oral anticoagulation in selected patients, though the evidence (for efficacy) was deemed low-strength, and high rates of serious procedure-related harms were noted in many studies. Specific comparisons between devices or patient groups was not possible due to insufficient evidence; most notably this included the subgroup of patients who are ineligible for long-term oral anticoagulation. Though additional harms appeared low with surgical procedures for LAA exclusion/resection, there was insufficient evidence to evaluate efficacy, with some studies suggesting low procedural success. For this reason the routine use of surgical LAA exclusion for the purpose of stroke prevention or cessation of anticoagulation could not be recommended. Dr. Noelck and team should be congratulated for an exhaustive and fair review. Some specific comments follow. | Thank you.
Additional suggestions or comments can be provided below. If applicable, please indicate the page and line numbers from the draft report. | 5 | Major: 1. Perhaps due to the structure of the key questions there is no direct comparison of risks of intervention versus standard of care (long-term oral anticoagulation). Within key question #1 the harms of stroke or death are addressed in a comparative fashion. Key question #2 primarily examines all other harms only on the side of intervention. This may bias the reader's resulting assessment of the risks and benefits between intervention and anticoagulation. I do agree with the assessment that percutaneous intervention on the LAA has had high rates of serious procedure-related harms in many studies (perhaps lessening with experience, as the authors mentioned). Given the indefinite nature of the risks of anticoagulation though, if a patient has a reasonable life expectancy, this risk will likely eventually be equaled and surpassed. A bit more detailed statement of risks on the standard of care side of the equation, other than the brief mention of its “cumbersome” nature in the introduction would seem to be appropriate. | Addressed in discussion (page 36).
Additional suggestions or comments can be provided below. If applicable, please indicate the page and line numbers from the draft report. | 5 | Minor: 1. Might be reasonable to add a sentence to the findings in the harms row of the table on 3 in the executive summary that pertains to harms found specifically with Watchman device (even if only to say percentages fit in range above), since that is the only percutaneous intervention in which efficacy was addressed, ie, the most relevant. | Added Watchman example of periprocedural event rates (from RCTs PROTECT & PREVAIL) to executive summary of findings.
Additional suggestions or comments can be provided below. If applicable, please indicate the page and line numbers from the draft report. | 5 | 2. In Table 1 p9 PICOTS and key questions for percutaneous LAA interventions time on bypass is listed as an outcome for KQ2, presumably for symmetry with Table 2. Might favor listing need for surgical intervention instead. Ventilator days also probably is less relevant for percutaneous intervention category, whereas device migration or emboli formation could potentially be included. | Agree. Revised as suggested.
Additional suggestions or comments can be provided below. If applicable, please indicate the page and line numbers from the draft report. | 5 | 3. In Table 2 p10 PICOT and key questions for surgical LAA interventions the comparator for KQ2 is listed as surgery for atrial fibrillation without LAA removal. To my review, studies included in this comparison were primarily CABG and/or valve surgeries with or without LAA intervention. It would be surprising to find a study of surgery for AF only/specifically that did not include intervention on the LAA. | We agree, we searched more broadly but did not find any studies on these.
Additional suggestions or comments can be provided below. If applicable, please indicate the page and line numbers from the draft report. | 5 | 4. In Table 3 p17, might consider adding DM statistics to patient characteristics as all other aspects of CHADS score already included. Is it of interest to add race as well? | Agree, and we have added data on DM. Information on race was mostly unreported among both RCTs and observational studies.
Additional suggestions or comments can be provided below. If applicable, please indicate the page and line numbers from the draft report. | 5 | 5. KQ4 text on p22 addresses comparison of surgical techniques. Ref 28, Healey et al, also reported comparison numbers between stapler and suture technique, which were different. Is there a reason this data / inconsistency was not mentioned? | While this study reported results for both stapler and suture LAA occlusion, the surgical technique was not randomized. Over time the percentage of surgeries performed using staplers increased, making it difficult to determine whether it was increasing surgeon experience or change to stapler technique that led to higher rates of successful LAA occlusion.