# LAA DEVICE MANUFACTURERS

Scientific information requests were sent January 17, 2015, to the companies listed below.

LAA exclusion device | Device manufacturer
AMPLATZER™ Cardiac Plug, Cardiac Plug 2, Cardiac Plug 3, and Amulet™ | ST. JUDE MEDICAL, INC. ATTN: Medical Information Officer St. Jude Medical, Inc. One St. Jude Medical Drive St. Paul, MN 55117-9983 Email form: http://sjm.com/corporate/data/forms/email-us
ATRICLIP® PRO LAA Occlusion System | ATRICURE, INC. ATTN.: Medical Information Officer 6217 Centre Park Drive West Chester, OH 45069 Email form: http://www.atricure.com/contact-atricure-usa
WATCHMAN® Left Atrial Appendage Closure Device | BOSTON SCIENTIFIC, CORP. ATTN: Medical Information Officer 100 Boston Scientific Way Marlborough, MA 01752 Online form (scroll to bottom right): https://www.bostonscientific.com/en-US/contact-us.html
COHEREX WAVECREST™ LAA Occluder System | COHEREX MEDICAL, INC. ATTN: Medical Information Officer 3598 West 1820 South Salt Lake City, UT 84104 Online contact form: http://www.coherex.com/contact/
Lifetech LAmbre™ Left Atrial Appendage Occluder Device | LIFETECH SCIENTIFIC (SHENZHEN) CO., LTD. ATTN.: Medical Information Officer Cybio Electronic Building, Langshan 2nd Street, Nanshan District, Shenzhen 518057, PEOPLE'S REPUBLIC OF CHINA Email: lifetechmed@lifetechmed.com
LARIAT® Suture Delivery Device | SENTREHEART, INC. ATTN: Medical Information Officer 300 Saginaw Drive Redwood City, CA 94063 Email: info@sentreheart.com
LigaSure™ | COVIDIEN ATTN: Michael Tarnoff, MD FACS Corporate Chief Medical Officer Medical Devices/Medical Supplies 15 Hampshire Street Mansfield, MA 02048