# QUALITY ASSESSMENT

Table 9 Quality assessment of trials of percutaneous LAA interventions

Study | Was the allocation sequence adequately generated? | Was allocation adequately concealed? | Was knowledge of the allocated intervention adequately prevented during the study? | Were incomplete outcome data adequately addressed? | Are reports of the study free of suggestion of selective outcome reporting? | Was the study apparently free of other problems that could put it at a high risk of bias? | Summary assessment High/Low/Unclear Risk of Bias | Study was funded by
PREVAIL Holmes, 2014^16^ | Yes: “computer-generated randomization” for most of the subjects: 407 were enrolled thru randomization; the remaining 68 were enrolled through “roll-in process” | Yes Centralized system performed block randomization stratified by clinical center; password protected; accessed by PI and study coordinator | No: Participants and clinicians were not masked to treatment assignment | Yes, presumably: “All follow-up information from the post-182-day period was used in the final hazards analysis in the model, contributing to the calculation of the probability of 18-month events.” | Yes | Yes | Low | Atritech/Boston Scientific.
PROTECT AF Alli, 2013^12^ Holmes, 2009^13^ Reddy, 2013^14^ Viles-Gonzales, 2012^45^ | Yes: “randomly assigned by a computer-generated randomization sequence” in a 2:1 intervention:control ratio | Yes Centralized system performed block randomization stratified by clinical center; password protected; accessed by PI and study coordinator | No: Participants and clinicians were not masked to treatment assignment | Yes. Reports “Analyses were performed on randomized subjects for those with a paired mental and physical component score at baseline and 12 months, or in subjects who died before 1 year of follow-up irrespective of actual treatment received, following the intention-to-treat principle.” Caveat: patients with unsuccessful implantation were censored at 45 days and, therefore, did not have 12 month reported QoL data and were excluded. | Yes | Yes | Low; High for QOL outcomes owing to lack of blinding, subjective nature of the outcome, and differential rates of follow-up for this outcome. | Atritech, Inc.

Table 10 Quality assessment of trials of surgical LAA interventions

Study; Setting | Was the allocation sequence adequately generated? | Was allocation adequately concealed? | Was knowledge of the allocated intervention adequately prevented during the study? | Were incomplete outcome data adequately addressed? | Are reports of the study free of suggestion of selective outcome reporting? | Was the study apparently free of other problems that could put it at a high risk of bias? | Summary assessment High/Low/Unclear Risk of Bias
Nagpal, 2009^29^ Single center Italy | Yes: “Simple randomization, stratified by presence of preoperative atrial fibrillation, was carried out using a computer program” | Yes: “sealed-envelope technique was used to assign each patient to a treatment group” | Yes: “sealed-envelope” | Yes: ITT analysis | Yes | Yes | Low
Whitlock, 2013^31^ LAAOS II | Yes “participants were randomly assigned to either the occlusion arm or the no-occlusion arm by a central 24-hour automated interactive voice-activated randomization system. Treatment allocation was performed according to a computer-generated randomization list and was stratified based on preoperative OAC use.” | Yes | Yes “Treatment was not blinded” but unlikely that outcomes measured would be influenced by lack of blinding. “Although the study will not be blinded, the following steps will be taken to reduce the risk of bias in the assessment of outcome events. Patients will be assessed by standardized questionnaire at each visit. All reported outcome events will be reviewed by an adjudication committee blinded to treatment allocation. All hospital admissions occurring during the study will be reported, including all admission and discharge diagnoses, to detect possible stroke.” | Yes “Assessment of the secondary clinical outcomes was based on the intention-to-treat principle, in which all participants are included in their assigned treatment groups regardless of actual surgical procedure performed.” “One-year data were available for 100% of the patients enrolled in the LAAOS II trial.” | Yes | Yes | Low
Healey, 2005^30^ LAAOS | Yes “consecutively ordered, opaque, sealed envelope” “randomized, using sealed envelopes, to undergo LAA occlusion or serve as a control. Patients were randomized 2:1, favoring occlusion.” | Yes | Yes “Treatment was not blinded” but unlikely that outcomes measured would be influenced by lack of blinding. “Although the study will not be blinded, the following steps will be taken to reduce the risk of bias in the assessment of outcome events. Patients will be assessed by standardized questionnaire at each visit. All reported outcome events will be reviewed by an adjudication committee blinded to treatment allocation. All hospital admissions occurring during the study will be reported, including all admission and discharge diagnoses, to detect possible stroke.” | Yes no missing outcome data for KQ2 | Yes prespecified outcomes (Crystal 2003) all reported | Yes | Low risk of bias

Table 11 Quality assessment of cohort studies surgical LAA interventions

Study | Representativeness of the exposed cohort | Selection of the non exposed cohort | Ascertainment of exposure | Demonstration that outcome of interest was not present at start of study | Comparability of cohorts on the basis of the design or analysis | Assessment of outcome | Was follow-up long enough for outcomes to occur? | Adequacy of follow up of cohorts
Kim, 2013^33^ | 1 all patients who underwent surgery with a single cardiothoracic surgeon over the course of 10 years | 1 | 1 | 1 | 2 study controls for 8 variables in PSM model | 1 | 1? only looks at 30 days post-op, difficult to say how this would change the data. Could see more of a benefit in decreased CVA in the LAA ligation group with longer follow-up, however may have also seen more harm from the increased incidence of post-op AF. | 1 A total of 2078 patients underwent cardiac surgery during the 10-year study time period. Eleven patients were excluded from the study (10 patients died and 1 patient had an incomplete medical record because of transfer to another facility on postoperative day 1), leaving a sample size of 2067.
Lee, 2014^32^ | 1 | 1 | 1 | 1 | 2 PSM model with 20 variables | 1 | 1 | 1
Kanderian, 2008^34^ | 0 only 173 of 1,546 who underwent surgical LAA closure (follow-up complete TEE with color Doppler interrogation of LAA) | 1 | 1 | 1 | 0 | 1 | 1 | 1
Muhammad, 2014^35^ | 0 | 1 | 1 | 1 | 0 | 0 | 1 | 1

Newcastle-Ottawa10 criteria and code definitions used in Table 10:

- Representativeness of the exposed cohort
  1 = truly representative of the average pt in the community
  1 = somewhat representative of the average pt in the community
  0 = selected group of users eg nurses, volunteers
  0 = no description of the derivation of the cohort
- Selection of the non exposed cohort
  1 = drawn from the same community as the exposed cohort
  0 = drawn from a different source
  0 = no description of the derivation of the non exposed cohort
- Ascertainment of exposure
  1 = secure record (eg surgical records)
  1 = structured interview
  0 = written self-report
  0 = no description
- Demonstration that outcome of interest was not present at start of study
  1= yes
  0 = no
- Comparability of cohorts on the basis of the design or analysis
  Add points: Minimum 0 , Maximum 2
  1 = study controls for ___ (select most important factor)
  1 = study controls for any additional factor (a second important factor)
  0 = no adjustment for potential confounders
- Assessment of outcome
  1 = independent blind assessment
  1 = record linkage
  0 = self-report
  0 = no description
- Was follow-up long enough for outcomes to occur?
  1 = yes (need to define adequate follow up period for outcome of interest)
  0 = no
- Adequacy of follow up of cohorts
  1 = complete follow up; all subjects accounted for.
  1 = subjects lost to follow up unlikely to introduce bias; small number (define %) lost, or description was provided of those lost.
  0 = follow up rate < ____% (define adequate %) and no description of those lost.
  0 = no statement