# STUDY SELECTION

Code | Definition | KQ1. What is the effectiveness of LAA exclusion interventions compared with usual care? | KQ2. What are the harms associated with LAA exclusion? | KQ3a. How do the benefits LAA exclusion vary in different subgroups? KQ3b. How do the harms of LAA exclusion vary in different subgroups? | KQ4. What are the comparative effects of different techniques on health outcomes and rates of procedural success?
I – Surg | Addresses KQ1, KQ2, or KQ3: Primary trial or cohort study that compares surgical LAA technique with usual care, and reports outcomes of interest. | [underlined: Included surgical interventions:]; - LAA occlusion/removal techniques that involve major surgery (sternotomy or thoracotomy), eg:; ▪ specific devices such as AtriClip, or; ▪ techniques such as stapling or suturing.; - LAA occlusion/removal via thoracoscopic surgery, eg:; ▪ Thoracoscopic Left Appendage Total Obliteration No cardiac Invasion (LAPTONI) procedure; - Minimally invasive Maze procedures if there are data about the incremental effects of concomitant LAA exclusion.
I – Perc | Addresses KQ1, KQ2, or KQ3:; - For all KQs, include RCTs that compare percutaneous LAA technique with usual care, and reports outcomes of interest.; - For KQ2 and KQ3b, may also include cohort, registry, trial extension, or post market surveillance studies that report harms data and have a sample size >50. | [underlined: Included percutaneous interventions:]; - AMPLATZER™ Cardiac Plug (company: AGA Medical, Corp., North Plymouth, MN, USA) a.k.a. “Amulet”; - WATCHMAN® Left Atrial Appendage Closure Technology/Device/System (company: Atritech, Inc., North Plymouth, MN, USA); - PLAATO™ Percutaneous Left Atrial Appendage Transcatheter Occlusion (company: Appriva Medical, Inc., Sunnyvale, CA); - Coherex WaveCrest™ LAA Occluder System (company: Coherex Medical, Inc., Salt Lake City, Utah, USA); - LARIAT suture delivery device (SentreHeart, Redwood City, California); - Lifetech LAmbre™ Left Atrial Appendage Occluder Device (Lifetech Scientific Co., Ltd., Shenzhen, CHINA)
I4 – Surg | Addresses KQ4: Primary trial or cohort study that compares different surgical techniques to close LAA, and reports either procedural or health outcomes. | [underlined: Included outcomes for] KQ4:; - Procedural outcomes: successful closure/LAA removal, assessed by methods such as transesophageal echocardiogram; CT; MRI.; - Health outcomes: stroke, mortality, cardiovascular morbidity, or other reported health outcomes
I4 – Perc | Addresses KQ4: Include RCTs only. Study compares different percutaneous LAA techniques, and reports either procedural or health outcomes.
I–SR | Systematic review or meta-analysis of surgical / percutaneous techniques that addresses any of the 4 KQs