# SEARCH STRATEGIES

Database Strategy:

- Medline (Ovid)
- Embase (Elsevier)
- Cochrane Library (EBM Reviews)
- Conference Papers Index (ProQuest)

Grey Literature Sources

- Clinicaltrials.gov
- WHO ICTRP
- ISRCTN Registry
- US FDA medical devices website: Advisory Committee/Panel Meetings (CDRH); Premarket Approvals (PMA); Premarket Notifications (510(k)s)
- Device manufacturer scientific information request

Ovid MEDLINE(R) and Ovid OLDMEDLINE(R) 1946-November Week 3 2014, Ovid MEDLINE(R) In-Process & Other Non-Indexed Citations January 06, 2015

Searched: January 7, 2015

1 | atrial appendage/ and left.ti,ab. | 1060
2 | (left adj1 ((atrial or atrium or auricular) adj1 appendage*)).ti,ab. | 2410
3 | 1 or 2 | 2552
4 | Atrial Fibrillation/su or exp cardiovascular surgical procedures/ or ligation/ or thoracic surgical procedures/ or sternotomy/ or thoracoscopy/ or thoracic surgery, video-assisted/ or thoracotomy/ or (excis* or excision* or occlude* or occlusion* or closure* or destruction or obliterat* or ligation* or ligat* or sutur* or exclusion* or exclud* or appendectom* or thoracoscop* or minithoracotom* or mini-thoracotom* or stapling or stapled or stapler* or sew or sewn or oversew* or clamp* or clip* or atriclip or Gillinov-Cosgrove or ligasure or amputat* or resect* or removal or remove* or surger* or surgical or CABG or MAZE or AVR or sternotom* or percutaneous* or Watchman or Lariat or PLAATO or Amplatzer or Coherex or LAmbre).ti,ab. | 2716235
5 | 3 and 4 | 1457
6 | remove duplicates from 5 | 1421
7 | limit 6 to “all child (0 to 18 years)” | 145
8 | limit 7 to “all adult (19 plus years)” | 48
9 | 7 not 8 | 97
10 | 6 not 9 | 1324
11 | animals/ not humans/ | 4025968
12 | 10 not 11 | 1213

ELSEVIER EMBASE.COM : 1950-present

Searched: January 7, 2015

#13 | #9 NOT #12 | 2,164
#12 | #10 NOT #11 | 373
#11 | #10 AND ({young adult}/lim OR {adult}/lim OR {middle aged}/lim OR {aged}/lim OR {very elderly}/lim) | 68
#10 | #9 AND ({newborn}/lim OR {infant}/lim OR {child}/lim OR {preschool}/lim OR {school}/lim OR {adolescent}/lim OR {animal experiment}/lim OR {animal model}/lim) | 441
#9 | #7 OR #8 | 2,537
#8 | ‘left atrial appendage closure device’/exp | 184
#7 | #3 AND #6 | 2,485
#6 | #4 OR #5 | 4,435,729
#5 | ‘heart atrium fibrillation’/exp AND ‘surgery’/lnk OR ‘cardiovascular surgery’/de OR ‘ligation’/de OR ‘thorax surgery’/de OR ‘sternotomy’/de OR ‘thoracoscopy’/de OR ‘thoracotomy’/de | 110,162
#4 | excis* OR excision* OR occlude* OR occlusion* OR closure* OR destruction OR obliterat* OR ligation* OR ligat* OR sutur* OR exclusion* OR exclud* OR appendectom* OR thoracoscop* OR minithoracotom* OR mini AND thoractom* OR stapling OR stapled OR stapler* OR sew OR sewn OR oversew* OR clamp* OR clip* OR atriclip OR ‘gillinov cosgrove’ OR ligasure OR amputat* OR resect* OR removal OR remove* OR surger* OR surgical OR cabg OR maze OR avr OR sternotom* OR percutaneous* OR watchman OR lariat OR plaato OR amplatzer OR coherex OR lambre.ti,ab. | 4,421,880
#3 | #1 OR #2 | 4,759
#2 | ((atrial OR atrium OR auricular) NEXT/1 appendage*):ab,ti | 4,553
#1 | ‘heart atrium appendage’/exp AND left:ab,ti | 2,855

Ovid EBM Reviews:

- Cochrane Central Register of Controlled Trials: 1991-November 2014
- Cochrane Database of Systematic Reviews: 2005-November 2014
- Database of Abstracts of Reviews of Effects: 1991-4th Quarter 2014
- Health Technology Assessment: 2001-4th Quarter 2014
- NHS Economic Evaluation Database: 1995-4th Quarter 2014

Searched: January 7, 2015

1 | (left adj1 ((atrial or atrium or auricular) adj1 appendage*)).mp. | 79
2 | (excis* or excision* or occlude* or occlusion* or closure* or destruction or obliterat* or ligation* or ligat* or sutur* or exclusion* or exclud* or appendectom* or thoracoscop* or minithoracotom* or mini-thoracotom* or stapling or stapled or stapler* or sew or sewn or oversew* or clamp* or clip* or atriclip or Gillinov-Cosgrove or ligasure or amputat* or resect* or removal or remove* or surger* or surgical or CABG or MAZE or AVR or sternotom* or percutaneous* or Watchman or Lariat or PLAATO or Amplatzer or Coherex or LAmbre).mp. | 153735
3 | And/1-2 | 45

ProQuest COS Conference Papers Index

Searched: January 22, 2015

(left atrial appendage* OR left atrium appendage* OR left auricular appendage*) AND (excis* OR excision* OR occlude* OR occlusion* OR closure* OR destruction OR obliterat* OR ligation* OR ligat* OR sutur* OR exclusion* OR exclud* OR appendectom* OR thoracoscop* OR minithoracotom* OR mini-thoracotom* OR stapling OR stapled OR stapler* OR sew OR sewn OR oversew* OR clamp* OR clip* OR atriclip OR Gillinov-Cosgrove OR ligasure OR amputat* OR resect* OR removal OR remove* OR surger* OR surgical OR CABG OR MAZE OR AVR OR sternotom* OR percutaneous* OR Watchman OR Lariat OR PLAATO OR Amplatzer OR Coherex or Lambre)

[Search field=anywhere; document type=conference, conference papers; dates=all dates]

Results=57

ClinicalTrials.gov

https://www.clinicaltrials.gov/ct2/search/advanced

Searched: July 28, 2015

Search terms = “left atrial appendage” OR “left atrium appendage” OR “left auricular appendage”

Study type = Interventional Studies

Results = 58

World Health Organization International Clinical Trials Registry Platform (WHO ICTRP)

http://apps.who.int/trialsearch/

Searched: January 22, 2015

Search terms: Watchman OR Amplatzer OR Coherex OR Wavecrest OR Ligasure OR Lambre OR PLAATO OR Atriclip OR Lariat OR left atrial appendage OR left atrium appendage OR left auricular appendage

Results = 3

ISRCTN Registry

http://www.isrctn.com/editAdvancedSearch?q=plaato&filters=&searchType=advanced-search

Searched: January 22, 2015

Searched each of the following terms/phrases separately in the text search field:

- Watchman OR Amplatzer OR Coherex OR WaveCrest OR Ligasure OR Lambre OR PLAATO OR Atriclip OR Lariat OR left atrial appendage OR left atrium appendage OR left auricular appendage

Results = 0