# ABBREVIATIONS

ACP: Amplatzer cardiac plug
AF: Atrial fibrillation
CABG: Coronary artery bypass grafting
CAD: Coronary artery disease
CHADS2: Stroke risk score in AF (congestive heart failure, hypertension, age 75+, diabetes mellitus, and stroke/TIA)
CHA2DS2-VASc: Stroke risk score in AF that includes CHADS2 with age in 2 categories and vascular disease
CHF: Congestive heart failure
CI: Confidence interval
CT: Computerized tomography
DM: Diabetes mellitus
HAS-BLED: Score that estimates risk of major bleeding for patients on anticoagulation for atrial fibrillation
HR: Hazard ratio
HTN: Hypertension
Hx: History (of)
INR: International normalized ratio
LAA: Left atrial appendage
LT-OAC: Long-term oral anticoagulation therapy
LVEF: Left ventricular ejection fraction
MI: Myocardial infarction
MRI: Magnetic resonance imaging
PICOTS: Population, Intervention, Comparator, Outcome, Timing, Study Design
PLAATO: Percutaneous Left Atrial Appendage Transcatheter Occlusion
PSM: Propensity score matching
QoL: Quality of life
RCT: Randomized controlled trial
RR: Relative risk
TEE: Transesophageal echocardiography
TIA: Transient ischemic attack
VATS: Video assisted thoracoscopy
WHO ICTRP: World Health Organization International Clinical Trials Registry Platform